# SECTION 6 POLICY CONSIDERATIONS AND RESEARCH

Recommendations in the literature and from SME interviews pointed to several potential policy levers to increase interoperable EHR adoption and use among LTPAC providers. They indicated that the population served in LTPAC represents patients with multiple chronic conditions and high health care costs presenting opportunities for great potential impact with new policies and innovations. SME groups identified emerging opportunities with policy changes such as with dQMs and public health reporting. Across the SME groups they shared a desire to increase conversations between care settings and providers, between payers and CMS/ONC, and across HIE/HINs to coordinate on needs, priorities, policies, standards, initiatives, and communication. The themes and ideas for policy considerations and research based on the environmental scan and SME interviews are discussed below.

## 6.1 Address the Policy Barriers that Limit Long-Term and Post-Acute Care Inclusion in Health Information Technology and Interoperability Advances

• Consider Statutory Limitations to Include LTPAC in HIT Policies. Policy makers in the literature and from SME interviews pointed to several potential policy levers to increase interoperable EHR adoption and use among LTPAC providers. They indicated that the population served in LTPAC represents patients with multiple chronic conditions and high health care costs presenting opportunities for great potential impact with new policies and innovations. SME groups identified emerging opportunities with policy changes such as with dQMs and public health reporting. Across the SME groups they shared a desire to increase conversations between care settings and providers, between payers and CMS/ONC, and across HIE/HINs to coordinate on needs, priorities, policies, standards, initiatives, and communication. The themes and ideas for policy considerations and research based on the environmental scan and SME interviews are discussed below.
• Explore Barriers and Facilitators to Participate in CEHRT and ONC Health IT Certification Program. Use of certified HIT according to the CMS Certified Electronic Health Record Technology (CEHRT) definition is a foundational requirement for some programs (e.g., electronic quality measure reporting, some value-based care models and innovations). The requirement to adopt and use CEHRT does not apply to LTPAC, however, SMEs noted challenges with participating in current CMS value-based care and innovation models due to this requirement and the potential future impact if not addressed.

The ONC Health IT Certification Program promotes a modular ecosystem of HIT for settings beyond those previously eligible for the EHR Incentive Programs, such as for LTPAC. Through the ONC Health IT Certification Program, providers across the care continuum have improved access to technical standards that form an essential foundation for interoperability and help ensure that key data is consistently available to the right person, at the right place, and at the right time. Certification criteria supports settings and use cases across the care continuum – including for LTPAC where such criteria are voluntary to adopt as part of the CMS payment program. SMEs shared that the lack of drivers for voluntary certification, such as a CMS payment model, quality or public health reporting requirement, or regulation, has resulted in limited awareness of LTPAC providers to request certification of their vendors.

## 6.2 Spur Adoption of Interoperable Health Information Technology in Long-Term and Post-Acute Care Settings

- Consider Policy Options to Increase Adoption. Investigate interest and considerations for incentive programs (financial and other) to increase adoption and use of interoperable/certified EHRs and reward information-sharing by LTPAC. Evaluate opportunities such as those with quality payment programs, payment models that provide opportunities for LTPAC (e.g., institutional special needs plan, dual eligible special needs plan, and accountable care organizations), and new innovations in value-based care models targeting LTPAC populations and settings.
- Understand the Effectiveness of Past Policies, Funding, and Interventions. Understand past policy interventions applied to LTPAC and their effectiveness (e.g., Promoting Interoperability, funding to HINs, and financial matching programs) to determine outcomes achieved, feasibility for roll-out on a national scale, and potential impact.
- Recognize Related Workforce Training and Support Needs. Findings in the literature and feedback from SMEs stress that policies to increase adoption and use of interoperable HIT must consider workforce training and resources needed to support implementation and workflow redesign. Investments that support staff training could incorporate HIT skills-building to promote use of HIT.

## 6.3 Coordinate on Interoperability Priorities, Policies, Standards, and Communication

- Convene a Cross-HHS LTPAC Interoperability Working Group. Increase communication and coordination across agencies focused on including LTPAC in broader HIE/HIN planning, requirements, or activities. The workgroup could explore opportunities to further coordinate and collaborate on data harmonization/alignment to advance LTPAC interoperability using existing tools/resources (e.g., CMS DEL or CDC NHSN) and the ONC USCDI, etc. Collaboration could also include engaging HIE/HINs to share opportunities, policies, and case studies that have increased LTPAC participation. For example, one state HIN supports their state Medicare Advantage Dual-Eligible Special Needs Plan data-sharing requirements and onboarded all SNFs who report admission, discharge, and transfer information with the HIN.
- Understand Bidirectional Data Sharing Priorities and Standards for Providers. Policy makers seeking to align requirements, standards initiative, funding opportunities, and analytic strategies would be well-served to stay informed of providers’ data sharing priorities and gaps. Data sharing/exchange priorities and policies identified include increasing electronic data sharing compatibility for two-way communication between hospitals and LTPAC providers via national standards. Priority areas include information exchange for transition and continuity of care, such as:
  ○ Transition of care, referral, and detailed aspects of medication management (additions, changes, and discontinuation of medications).
  ○ Sharing of advance directive with an individual’s care team including their pharmacist.
  ○ Use of an electronic shared care plan that includes therapies implemented, revised, or stopped.
  ○ Patient status changes.
- Utilize HHS Communication Tools to Build Awareness and Educate LTPAC Settings on Interoperability. In the absence of policy levers and programs to advance interoperability, it may be helpful to strengthen communication and education approaches to discuss the importance of interoperability and use of HIE standards in LTPAC EHRs. Include real-world case studies, standards implementation success stories such as from the PACIO project, and findings from research studies on information-sharing. Lastly, discuss the value and efficiency gains from utilizing standardized data collected at the point of care to support administrative reporting requirements.

## 6.4 Improve Health Information Exchange Across Platforms, Networks, and Geographies

- Consider Value Proposition for LTPAC to Participate in HIE/HINs. To commit both financially and data resources to an HIE/HIN, LTPAC providers must receive a benefit or have a business reason to participate. Investigate how the value proposition can be improved for LTPAC. HINs noted a misaligned incentives -- LTPAC patient data is needed by stakeholders for population health, public health, care coordination, quality management and cost management -- but value back to the LTPAC setting is limited because they are not receiving the data needed.
- Improve Ease of Data Sharing. The current state for HINs does not allow for easy data sharing and thus there is very little insight into who owns, manages, and controls the data. Common standards and technical approaches for interoperability and information exchange will help overcome barriers to data sharing. An emerging opportunity to address this is the Trusted Exchange Framework and Common Agreement.
- Clarify HIE/HIN, Vendor, and Provider Relationships. In the LTPAC market, a few technology platform vendors support a large number of providers. Issues have emerged with ownership, management, and control over data exchange. Clarification and policies are needed on data governance policies for HIE including the data ownership is centered around the vendor and HIE or the HIE and provider/covered-entity. The 2020 ONC Cures Act Final Rule could help address potential information blocking concerns and data governance policies as noted by SMEs.

## 6.5 Investigate Telehealth Policy, Planning, Use, and Research in Long-Term and Post-Acute Care

- Explore Opportunities in Telehealth by LTPAC Settings. COVID-19 has had an impact on telehealth regulations and caused states and LTPAC providers to re-evaluate their ability to use technology and telehealth to perform care. Preliminary work suggests LTPAC, specifically nursing homes, are likely to use telehealth post-pandemic (Wicklund, 2021). Identifying opportunities for telehealth in LTPAC can support policies including reimbursement, regulations, technology preparedness, and potential outcomes. Study domains could address these domains plus the following questions:
  ○ Who is not eligible for the expansion of telehealth services? Who would be left out (providers or patient populations)?
  ○ What barriers exist? For example, what communities do not have access to broadband internet? How will challenges with technology adoption to support telehealth be overcome if knowledge does not exist and training is needed? Will cost and workflow changes deter adoption in LTPAC?