# SECTION 5 CURRENT AND EMERGING USES FOR TECHNOLOGY IN CARE COORDINATION AND REPORTING

Adoption data shows that the majority of LTPAC providers use EHRs in varying ways to support their specific clinical and administrative needs (see Appendix A for adoption studies and summary data). LTPAC EHRs have functionality including demographics, problem lists, vital signs, computerized physician order entry, medication lists, electronic notes, assessments, care plans, reporting, and more. While these features may be available to LTPAC providers, the extent of their use may vary based on barriers and facilitators described in Section 4. Appendix C provides a summary of EHR functionality available by vendors serving LTPAC providers based on the Center for Aging Services Technology EHR Selection Matrix. Ancillary service providers such as pharmacy, rehabilitation therapy, lab, and imaging are integral to the care team, but typically maintain separate systems that are not well-integrated with LTPAC EHRs. SMEs identified the lack of system integration is a pain point and opportunity to improve interoperability. Appendix C provides a detailed breakdown of LTPAC EHR functions in comparison to the EHR Incentive Program for hospitals and physician-offices.

To understand current and emerging uses for technology in care coordination and reporting, SMEs discussed: How are LTPAC providers using EHRs to coordinate care and/or report public health or quality data for patients via HIEs or exchange networks? Exhibit 5 and the supporting text capture the perspectives that SMEs provided about HIT’s current state and changes that are necessary to promote standards and interoperability for EHRs in LTPAC.

Exhibit 5 SME Comments on the Current and Emerging Uses for Technology in Care Coordination and Reporting

EXHIBIT 5: Shows thought balloons for the following 5 comments from SMEs: The lack of interoperability is holding back care coordination. COVID has “pulled the band-aid off the public HIT reporting system” to show how archaic it is. We hope to connect providers that had previously been forgotten. Every major health policy could be served by interoperability. It must start with dollars.

## 5.1 Uses for Technology in Care Coordination

Our search for examples of how LTPAC providers use EHRs generally yielded examples of HIT to support clinical and administrative processes. When discussing use of HIE for these clinical processes, the literature noted the challenges and resources needed to revamp the clinician’s workflow to include technology. (Alexander et al., 2015) The framework for describing types of care coordination from 2014 is still relevant based on our environmental scan, however there are new emerging examples and refinements that could be added to reflect a more contemporary picture of today’s care delivery and new administrative processes.

Exhibit 6 Byrne et al.’s Care Coordination Framework

EXHIBIT 6: Shows Byrne et al.’s Care Coordination Framework. A box at the top of the figure is titled “Transitions of care.” This includes assessment and referral, transfer or discharge, and follow-up. Below and to the left is a box titled “Shared Care,” which includes assessing needs and goals, creating and maintaining a plan of care, monitoring, follow-up, and responding to change. To the right is a box titled “Administrative Action,” which includes, billing, quality measure reporting, and public health reporting.

The care coordination framework characterizing three key activities involving LTPAC settings: transitions of care (between settings), shared care (e.g., physician working with a nursing home or HHA), and administrative actions. Exhibit 6 shows the structure and main elements of this framework. Transitions of care is further divided into three stages of the transition. These are assessment/referral, transfer or discharge, and follow-up. Shared care is also described in three parts: assess needs and goals; create and maintain plan of care; and monitor, follow-up, and respond to change. Administrative actions include billing, quality measure reporting, and public health reporting.

HIT can improve care coordination, but many care coordination benefits are unrealized because of the lack of interoperability. SMEs confirmed the importance of interoperable health IT to improve transitions of care, shared care, and administrative actions. They also mentioned that interoperability can help optimal sharing of information among stakeholders in value-based care settings. Interoperability could enable more access to patient data as patients move across care settings, particularly in and out of LTPAC settings. These gaps in information-sharing were made more publicly apparent during the COVID-19 pandemic and serve as a rationale for including LTPAC in interoperability discussions.

HIE/HIN SMEs called out their efforts to create an online case management system as a way to address interoperability gaps. They held out the example of the Carequality Interoperability Framework, a trusted bidirectional information exchange that integrates directly into EHRs (CareQuality, n.d.). A growing number of LTPAC settings as well as behavioral health stakeholders are utilizing the Carequality exchange environment. Underlying this is FHIR exchange (HL7 FHIR Exchange Network, n.d.) and, as with so many other health data interoperability efforts, HIE/HIN stakeholders are working with providers and vendors to make interoperable EHRs the catalysts for data exchange for care coordination.

## 5.2 Uses for Technology in Reporting

The sources we identified via the environmental scan generally do not provide examples of LTPAC providers using EHRs for reporting quality data or public health information via interoperable HIE or through HINs. For quality reporting today, post-acute care providers (SNF/nursing homes, HHAs, hospice, IRFs, and LTCHs) are required to electronically submit required assessment instrument or item set data to CMS through a web portal. This data may also be used for payment and regulatory oversight depending on the setting. In 2021, CMS shared plans to use FHIR as part of their dQM strategy including opportunities for post-acute care submissions. Today’s quality reporting programs provide a siloed view by care setting of quality measure performance. The dQM vision seeks to build an infrastructure that aligns quality measures across settings and patient populations to provide real-time data feedback and support value-based care. For LTPAC providers, SMEs note that aligning measures and moving toward interoperable solutions provides an opportunity to expand the use of clinical decision support (CDS), analytics, and artificial intelligence tools to enhance care delivery and coordination.

As previously discussed, SMEs shared the challenges of today’s public health reporting system with different reporting processes and data requirements by local and state governments. LTPAC providers report data as required by their local jurisdiction. The specific data requirements and reporting process varies widely from use of spreadsheets to state-specific systems. To address these issues, the Centers for Disease Control and Prevention (CDC) has released a 2022 roadmap for modernizing public health reporting in the United States. An example of an emerging innovation discussed by the SMEs is the National Healthcare Safety Network (NHSN) for infection tracking data and resources including for LTPAC providers. The COVID-19 pandemic highlighted the importance of technology tools for reporting, and public health infrastructure improvements to enable real-time data analysis and decision-making. For example, interoperable Health IT allow providers to efficiently report cases and other critical population health information to federal agencies, state, local, territorial, and tribal partners during public health emergencies. The Biden Administration issued an Executive Order in January 2021 on protecting public health and ONC is prioritizing both data standardization and workforce to improve the public health infrastructure (White House, 2021). This is an emerging area, and it is important for LTPAC providers to be included in both the technology planning and deployment.

Public health SMEs who participated in discussions with RTI emphasized that the COVID-19 pandemic has, “pulled the band-aid off the public health reporting system,” and revealed how archaic the public HIT infrastructure is. This was most apparent with regard to immunization data; LTPAC providers were not reporting to Immunization Information Systems. The SMEs discussed how the voluntary process of reporting leads to gaps or delays in the information the CDC and other agencies receive about reportable conditions from localities and states. The COVID-19 pandemic has shown that the public health challenge is compounded since LTPAC clinical documentation and pharmacy systems are not well-integrated with interoperable EHRs and they are hampered by a lack of uniform reporting.

SMEs noted that for comprehensive EHR reporting to succeed at any level within the United States, there needs to be a culture of data standardization at the national level. Otherwise, fragmented EHR reporting will remain across local, state, and federal levels, across care settings, and across care services. Adopting new standards like FHIR will be essential if LTPAC settings are to use EHRs to share data such as immunization information and social determinants of health with public health agencies.