# SECTION 4 BARRIERS AND FACILITATORS TO HEALTH INFORMATION TECHNOLOGY ADOPTION

Our environmental scan identified several barriers and facilitators to LTPACs adopting interoperable EHRs for data exchange with key stakeholders, and SME interviews supplemented these findings. Most have persisted over the past decade highlighting the challenge of finding solutions that make a widespread, sustainable impact.

We sorted the barriers and facilitators based on themes to bundle related topics. Exhibit 4 shows the applicable themes and demonstrates how certain barriers and facilitators are related to, and interact with, each other. All barriers could be alleviated with one or more corresponding facilitator -- except for culture of adoption/early support from important stakeholders, which was an overarching facilitator. Although there is some overlap in the general themes across these groups, the specific details of the barriers and facilitators, and potentially the solutions to the barriers, depend on the perspective from which they are experienced. SMEs generally agreed with the barriers and facilitators identified in the environmental scan.

Exhibit 4 Pervasive Barriers and Alleviating Facilitators to HIT Interoperability and Adoption for Data Exchange Over the Past 10 Years

EXHIBIT 4: Shows the Pervasive Barriers and Alleviating Facilitators to HIT Interoperability and Adoption for Data Exchange Over the Past 10 Years. These barriers and facilitators are explained in detail in the text.

## 4.1 Barriers to Health Information Technology Interoperability and Adoption for Data Exchange

Cost and lack of financial incentives were consistently mentioned as primary barriers, and they have a direct relationship to the sufficient funding facilitator. SMEs reiterated that sufficient operational funding facilitates successful interoperable HIT systems. Multiple SMEs referenced the lack of Meaningful Use/Promoting Interoperability program EHR requirements in the LTPAC setting as a driver of this incentive issue. Due to thin operating margins, lack of adequate financial incentives has made it difficult to fund and implement interoperable HIT systems. SMEs mentioned that without the proper financial incentives, it can be challenging to align policy, measures, and enforcement. The policy maker SMEs further indicated a general lack of authority to enforce existing HIT standards. Organizations need a system or market reason to exchange data. Without the proper financial and policy incentives, it will be difficult to make organic progress toward interoperability.

Sufficient funding, low user burden, and technology support all help alleviate workforce turnover and staffing shortage issues. As Exhibit 4 shows, the workforce turnover and inadequate training barrier is associated with multiple facilitators. Broadband connectivity issues are a serious barrier as related to staff education and user burden, especially in rural and underserved urban areas, thus highlighting a further technological challenge.

Organizations are afraid of sharing proprietary data with one another due to lack of communication between systems and across geographies. Public Health SMEs highlighted the inconsistency in state-level HIT interoperability policies and their use of standardized data across jurisdictions. Different requirements within and between states creates confusion, and these inconsistencies create extra expenses for organizations. SMEs from industry expressed frustration with a lack of guidance and communication from federal regulators. Except for interoperability initiatives related to the federally required assessment instruments mandated in the IMPACT Act, these SMEs noted that LTPAC organizations and vendors are left to do what they think is best, with limited guidance resulting in the lack of standardized and codified data to support interoperability. This general lack of consistency and lack of clear vision for future policies has also inhibited successful HIT adoption in LTPAC. There are startup costs to implement new requirements, but providers and vendors do not have a clear understanding of what data reporting and interoperability requirements will be in the future. Results from SME interviews suggest there is general frustration over a lack of sustainable strategy to implement interoperable HIT in LTPAC settings.

Data is needed from LTPAC organizations but the value proposition and business model to motivate interoperability organically doesn’t exist today.

## 4.2 Facilitators and Strategies that Increase Adoption and Interoperability

Although barriers create frustration and reduce adoption, SMEs also described recent programs and strategies that lead to increased adoption and interoperability by LTPAC. SMEs discussed the Fast Healthcare Interoperability Resources (FHIR) standard and described it as a useful tool for establishing clinical guidelines and incorporating them into reporting to facilitate care coordination and reporting by LTPAC providers. SMEs stressed the way to get regulatory traction is to integrate the quality measure and quality of care components together. Multiple SME groups identified the CMS Data Element Library (DEL) and PACIO (Post-Acute Care Interoperability) project supported by CMS as being helpful to engage the LTPAC providers and vendors in identifying and testing common information exchange scenarios using the emerging FHIR standards. Other SMEs cited the ONC 360X referral and transition of care projects as being helpful in increasing vendor participation by enabling providers to use existing health data exchange standards and technologies to exchange referral requests and relevant patient clinical information. The DEL, PACIO project and 360X projects all leverage the standardized and codified data elements from required CMS assessment instruments as the baseline for HIE. These targeted programs display how explicit data standards can facilitate integration of interoperability approaches, offering concrete steps to alleviate some potential adoption barriers. Despite this engagement by vendors, concern remained with the SMEs that providers will not revise their workflow to use the implementation tools in absence of a policy, program, or requirement for its use.

To address the interoperability gap and challenges identified with the COVID-19 pandemic, stakeholder advocacy efforts have emerged. The 2022 consensus report by the National Academies of Science, Engineering and Medicine recommended five strategies for HIT to improve nursing home quality. These strategies align with a coordinated advocacy effort underway by LTPAC association and organizations to request legislative funding to ensure that the policies and priorities for interoperability include the providers across the continuum of care.

National Academies of Science, Engineering and Medicine 2022 Study on the National Imperative to Improve Nursing Home Quality including Recommendations for HIT

- Identify pathways to provide financial incentives to nursing homes for certified EHR adoption.
- Develop and report measures of HIT adoption and interoperability.
- Measure and report nursing home staff, resident, and family perceptions of HIT usability.
- Development and ongoing implementation of training in core HIT competencies for nursing home leadership and staff.
- Rigorous evaluation studies of HIT use, disparities in HIT adoption and use, innovative HIT applications, and assessment of perceptions of HIT usability.

Source: The National Imperative to Improve Nursing Home Quality: Honoring Our Commitment to Residents, Families, and Staff. National Academies Press. https://nap.nationalacademies.org/catalog/26526/the-national-imperative-to-improve-nursing-home-quality-honoring-our.

## 4.3 New and Developing Barriers and Facilitators

SMEs mentioned several barriers and facilitators not identified in the environmental scan. With respect to facilitators, the SMEs noted the need or existence of a strong relationship between two or more providers. Strong relationships allowed for good communication regarding expectations and what modalities to use. A new barrier highlighted by the HIN SMEs was ownership and management of HIT data. From their perspective, some of the prominent HIT vendors perceive data ownership centering around the vendor and HIE rather than as the HIE and covered-entity relationship. The perception or perceived ownership of the data and the relationship when it comes to sharing that data can be a major barrier to interoperability. The lack of agreement about who owns the HIT data, can, and has, lead to legal disputes that inhibit interoperability and reduce operational efficiency.

The barriers and facilitators identified from the environmental scan predominantly reflected the provider perspective. While all SMEs agreed with the barriers and facilitators found in the literature, groups from other areas of the LTPAC industry may have different perspectives or nuanced opinions regarding the importance of certain barriers and facilitators, as well as the best methods to alleviate barriers and thus facilitate interoperable HIT adoption as seen through current and emerging uses in care coordination and reporting.