# SECTION 3 EVOLVING CURRENT STATE: LONG-TERM AND POST-ACUTE CARE INNOVATORS AND CHAMPIONS

As one SME described, LTPAC providers that have champions who see the value of interoperability and willingness to “push” to “make it happen” have generally made the greatest strides with respect to EHR use and data exchange. Champions have been critically important for EHR use and data exchange in hospitals and office-based settings (Shea, 2016). So, it is no surprise that they too are critically important for the LTPAC sector. These champions are up against challenges in convincing clinic staff who are reticent to take on additional reporting burdens and adopt HIT that does not fit into natural workflows.

Champions often see the early technologies and developments that improve operations. It is widely believed that new technologies have, and will continue to, impact how LTPAC providers deliver care. Telehealth, for example, experienced a 63-fold increase among fee-for-service Medicare beneficiaries between 2019 and 2020 (840,000 to 52.7 million visits) (Samson et al. 2021). Telehealth for SNFs and patient transfers or hospice only accounted for 7% of those 52.7 million visits. Improved training and support for telehealth may help alleviate workflow and technology challenges. The University of Missouri found that “despite the challenges, more skilled nursing facilities are recognizing the benefits of telehealth and are planning for post-pandemic use. With the right strategies in place, clinicians and administrators can help prevent the struggles that may accompany telehealth adoption” (Bailey, 2021; Powell & Alexander, 2021).

In addition to telehealth, early adopters are exploring or investing in an array of other technologies: remote patient monitoring, medication management, functional assessment and activity monitoring, shared care planning and coordination, social connectedness and engagement, safety, and data analytics (LeadingAge, 2021).