# SECTION 2 CURRENT STATE OF HEALTH INFORMATION TECHNOLOGY ADOPTION IN LONG-TERM AND POST-ACUTE CARE

Environmental scan results and focus group interviews with SMEs provided insight as to the current state of HIT adoption among LTPAC providers. SMEs provided insight into how LTPAC settings are currently adopting and using interoperable EHRs as well as telehealth to coordinate care, report quality and public health measures, and utilize HIE networks.

LTPAC providers individually use EHRs to support clinical and administrative processes. See Appendix C for LTPAC EHR functions. While clinical and administrative information is routinely exchanged between providers for admission, transition of care, and care coordination, the use of EHRs and HIE/HINs to share the information is less common (i.e., most LTPACs are using some type of an EHR within their organization but not using it to interact with other providers’ HIT systems or to integrate with key service providers such as pharmacy, rehab therapy, lab, and others). The lack of interoperability by LTPAC impedes continuity of care across settings and limits patient-centric and value-based care approaches.

The rate of EHR adoption varies by LTPAC setting type as shown in Exhibit 2. Full EHR adoption data are available in Appendix A. Nursing homes, skilled nursing facilities (SNFs), and HHAs have the highest estimated rates of adoption (84% in 2018 and 78% in 2017, respectively). It is somewhat difficult to compare functionality of LTPAC EHRs with hospital or office-based physician EHRs because, although they share some of the same functions (e.g., storing patient clinical care and medical histories, conveying alerts for known allergies, enabling electronic physician order entry), there is no federal program or requirement for incremental progress toward interoperability for LTPAC settings. See Appendix C for EHR functionality comparison and alignment. This resource provides a guide to features available for use and how they align to requirements in the Meaningful Use/Promoting Interoperability program.

Yet despite the lack of a federally-funded program and policy requirements, estimates of EHR adoption rates among nursing home and SNF providers, as well as HHAs, were greater than 78% in 2018, which is on par with EHR adoption in office-based primary care settings. Residential care settings were estimated to be much lower overall, at 26% -- higher than that for larger facilities and much lower for small facilities. Little adoption data is available on specialty hospitals since 2009.

Exhibit 2 Percent EHR Adoption Over Time by Care Setting

Notes: The definition of an EHR varied between surveys and over time, precluding comparisons between the surveys. Full EHR adoption data sources are shown in Appendix A. For comparison across care settings, IRFs and LTCHs and Residential Care Communities and Adult Day Services were excluded due to limited and or single year data across study period.

Hospitals*: Percent Basic EHR Adoption data from 2008–2010 and switches to certified EHR adoption data in 2011which is consistent with the meaningful use program regulations. Earliest surveyed year 2008 and latest surveyed year 2015 with all other years applied natural growth rate.

Office-Based Physicians**: Percent EHR Adoption of any EHR type (Basic, Certified, Other). Earliest surveyed year 2008 and latest surveyed year 2017 with all other years applied natural growth rate.

SNFs/NHs^: Results from EHR adoption surveys between 2004 and 2018 reflect variations in the definition of EHR between surveys and over time, however the observed incremental increase in adoption and use in NHs and SNFs parallels findings related to the adoption of “any EHR” among physician practices in this same time period. In the absence of a national standard such as for a certified EHR, surveys independently defined and described functions in a NH/SNF EHR. Earliest survey year was 2008 with a range of survey results and average included for Percent EHR Adoption Over Time analysis. Additional years of results were 2012, 2013, 2015, 2016, 2017 and 2018 with all other years applied natural growth rate.

Home Health/Hospice^^: Similar to NH/SNFs, HHAs and hospice providers adoption of EHRs has doubled over a decade between 2007 and 2017 and consistent with adoption of “any EHRs” by office-based physicians. Studies since 2013 have included both EHR functions and use of mobile technologies and telehealth. ONCs latest survey of SNFs and HHAs compared and found higher EHR adoption and interoperability domain use in HHAs. Survey data available for 2007, 2015, and 2017 with all other years applied natural growth rate.

EXHIBIT 2, Line Graph: Presents the percentage of EHR adoption over time, 2007-2018, in 4 different care settings: Hospitals, office-based physicians, skilled nursing facilities or nursing homes, and home health or hospice. The percentage of adoption has generally increased over time in each setting. In hospital settings, the percentage increased from a low of under 10% in 2007 to over 95% by 2014 and held steady between then and 2018. In office-based physician settings, the percentage increased from a low of approximately 40% in 2007 to a high of nearly 90% in 2015, and held steady between then and 2018. In SNFs and nursing homes, the percentage increased from a low of 30% in 2007 to a high of more than 80% by 2018. In home health and hospice settings, the percentage increased from 40% in 2007 to a high of nearly 80% in 2017 and 2018.

The COVID-19 pandemic has demonstrated the need for more effective interoperability of data among LTPACs and other care providers. Although there is broad consensus that LTPACs and their patients would benefit from greater access to HIT and information exchange, results from our interviews with SMEs suggest that those expectations do not match LTPAC financial resources. Policy makers and commercial vendors noted that, unlike with the Meaningful Use/Promoting Interoperability program, there are no levers or drivers requiring LTPAC providers to share information with hospitals and office-based settings. Exhibit 3 shows interoperability domains from the 2016–2017 ONC Survey of HHA, hospice, nursing home, and SNFs. Appendix A also provides summary data from EHR adoption studies and findings on interoperability domains published through 2021. Lacking a comprehensive federal strategy leaves LTPAC providers to contend with a web of state-level regulations and restrictions that act as barriers to any single comprehensive strategy for LTPAC EHRs.

Exhibit 3 Percent EHR Interoperability Domains by Care Setting

Note: ONC survey of EHR adoption and interoperability of HHAs including medication management (reconcile and record), methods of exchange, telehealth, and mobile technology use. (Henry et al., 2018)

ONC survey of EHR adoption and interoperability of SNFs including medication management (reconcile and record), electronic exchange, and methods of exchange. (Alvarado, Zook, & Henry, 2017; Henry, Pylypchuk, & Patel, 2018)

Survey questions assessing interoperability:

▪ [underlined: Find]: Do you or your staff electronically search or query for your patients' health information from sources outside your facility?

▪ [underlined: Send]: Do staff at your skilled nursing facility electronically send key clinical information such as labs, medications or problem lists to outside organizations on a routine basis? Electronic does not include fax, e-fax or MDS (minimum data set) quality reporting

▪ [underlined: Integrate]: Is staff easily able to integrate patient health information that you electronically receive into your EHR without manual entry or scanning?

EXHIBIT 3, Bar Charts: Shows the Interoperability Domain and Capabilities Adoption rates for HHA and hospice settings in a bar chart at left, and for SNFs and nursing facilities in a bar chart at right. According to the 2017 ONC survey, 41% of HHA and hospice settings had EHR systems with find capabilities, 52% had send capabilities and 36% had integrated capabilities. According to ONC surveys, in 2016, 20% of SNFs and nursing homes had EHR systems with find capabilities, 29% had send capabilities and 23% had integrated capabilities. In 2017, 27% of SNFs and nursing homes had EHR systems with find capabilities, 41% had send capabilities, and 18% had integrated capabilities.s

In interviews, SMEs explained that although SNFs and nursing homes have made some inroads connecting to HIEs and HINs, their participation remains low unless there was an ongoing funding mechanism or program in place. The potential reasons are multi-factorial, but SMEs pointed to barriers in care workflows and gaps in incentives to engage in data exchange. In the current climate, any connection SNFs and nursing homes have with other providers is seen as a win.