# SECTION 1 INTRODUCTION

Through strategic investments meant to spur HIT adoption in the form of certified EHRs by ambulatory practices and hospitals, many providers, patients, caregivers, public health entities, payers, and other stakeholders in the United States health care system are connected via interoperable data. After 10 years of these investments, over 85% of ambulatory practices and over 95% of hospitals have adopted and use some form of EHR to document patient care and share data to varying degrees. This amounts to a transformation in United States health care whereby stakeholders who have adopted EHRs can generate and share electronic patient data directly with each other or by way of intermediaries known as HIEs or HINs. Interoperable electronic patient data enable advances in care coordination, telemedicine, patient and public safety, and patient-centeredness.

LTPAC providers too have been adopting and using HIT including EHRs to support their clinical and business needs. Yet the level of adoption of interoperability features lags behind its counterparts in ambulatory and hospital settings. This is due to a variety of factors including a lack of systematic HIT investment for adoption, worker training, and more. This has led to capability gaps between the LTPAC settings and other parts of the United States health care system resulting in missed opportunities to share patient data and coordinate care among providers and caregivers in LTPACs, primary care, and hospitals. These gaps are becoming increasingly apparent due to a multitude of factors that include the general trend of an aging population and a health care system that is increasingly asked to deliver care for older adults with multiple chronic conditions.

Most acutely, the COVID-19 pandemic has put in stark relief the gaps between LTPAC and other health care settings (see Exhibit 1 for a typology of LTPAC providers). The Kaiser Family Foundation (KFF) found that as of June 30, 2021, over 35,000 LTPAC settings nationwide reported COVID-19 cases and that COVID-19 in long-term care facilities accounted for close to one-third (31%) of deaths as a share of state-level deaths (KFF, 2022). HIT and access to interoperable data via EHRs may benefit LTPAC and related settings with tools to better monitor signs and symptoms and coordinate responses with local and state public health departments (Andersen et al., 2021).

Increasingly, LTPAC settings rely on EHRs and the programs, standards, and requirements issued by federal and state agencies to define data standards and reporting requirements. Making policy choices that promote effective coordination among stakeholders requires an understanding of the LTPAC sector’s current state of EHR adoption and data exchange via HIE/HINs. This 2021–2022 study aimed to identify and summarize the latest information available on the LTPAC sector’s adoption and use of HIT and HIE/HINs including the barriers, facilitators, and policy levers. A description of the settings and providers reviewed for this study are described in Exhibit 1.

Exhibit 1 LTPAC Providers Identified for Study^*^

Institutions and Providers | Specialty Hospitals | Other Residential Care and Home and Community-Based Service Providers
Skilled Nursing Facility (SNF); Nursing Homes (NF); Home Health Agencies (HHA); Hospice Agencies | Inpatient Rehabilitation Facility (IRF); Long-Term Care Hospital (LTCH) | Assisted Living Facilities (ALF); Senior Living Communities (Sr. Living); Continuing Care Retirement Communities (CCRC); Program of All-inclusive Care for the Elderly (PACE); Adult Day Services

* Study Limitation: Comprehensive information about HIT/HIE adoption, use, and policies was not found on all settings listed in Exhibit 1. The majority of information found in the literature and discussed through SME interviews reflected a focus on SNF, NF, and HHA settings in LTPAC

To understand the adoption and use of HIT/HIE, the study team conducted an environmental scan including a literature review from 2011 to 2021 to identify and describe prior efforts to assess and analyze barriers and facilitators to adopting and using EHRs in LTPAC settings and potential policy levers influencing the sector’s decisions. The study focused upon three key questions:

1. What are the barriers and facilitators to LTPAC settings adopting interoperable EHRs for data exchange with key stakeholders?
2. How are LTPAC providers using EHRs to coordinate care and/or report public health or quality data for patients via HIE/HINs?
3. What are potential policy levers to increase EHR adoption and use among LTPAC providers to provide better care, public health reporting, etc.?

The environmental scan helped identify gaps in the published literature such as a lack of information about new and emerging technologies and opportunities within the sector. The research team explored these through interviews with SMEs. See Appendix B for detailed methodologies of the environmental scan, SME interviews, and study limitations. The seven interviews targeted researchers, providers/developers, HINs/HIEs, payers, public health reporting experts, and federal experts at the Centers for Medicare & Medicaid Services (CMS) and the Office of the National Coordinator for Healthcare Technology (ONC) with expertise in Interoperability Rule and Value Based Care. We chose these seven areas and identified SMEs to speak to each area based upon their critical work in the subject area in conjunction with the HIE and LTPAC space.

The SMEs provided unique insight on the gaps in the existing literature and how barriers and facilitators discussed in the literature were generally targeted for nursing homes and HHAs but not the broader LTPAC sector. The barriers and facilitators discussed often addressed areas specific to providers. When speaking with the SMEs, they shared additional barriers and facilitators from their perspectives (e.g., payer, public health, HIE/HINs, CMS/ONC). The SME interviews included researchers to hear their points of view regarding why there are gaps in the literature for barriers and facilitators. Additionally, we asked them to describe any current innovations that support better integration of EHRs into LTPAC settings. The researcher SMEs provided insight regarding ongoing studies and future research needs. These insights helped hone the interview questions for the other SME groups, such as payers and providers/developers who are integral to promoting HIE adoption and integration across the LTPAC sector.