# APPENDIX C ELECTRONIC HEALTH RECORD FUNCTIONALITY COMPARISON

Hospitals and professionals eligible for the EHR Incentive Program saw incremental changes over time to functionality and standards requirements to advance interoperability. Exhibit C-1 compares requirements over time from 2011 through 2021 to LTPAC EHR Functions. LeadingAge Center for Aging Services Technology maintains an EHR Selection Matrix Resource that includes information on system functionality gathered from 17 vendors that support the spectrum of LTPAC settings. Because LTPAC providers and settings were not eligible for the EHR Incentive Program or the current Promoting Interoperability Program, the functionality and standards may not align due to lack of requirements and/or customer request. The purpose of the exhibit is to help the reader understand the LTPAC system functions and uses compared to the interoperability programs.

Table C-1 Incremental Changes Over Time to Promote Interoperability and Certification Requirements for Eligible Hospitals and Providers Compared to LTPAC EHR Functions

EHR Incentive Program | | | | LTPAC EHR Function
Base EHR (2011) * | 2014 Edition Certification Criteria^**^ | 2015 Edition Certification Criteria^**^ | 2015 Edition Cures Update^***^ | LeadingAge Center for Aging Service Technology EHR Selection Matrix^****^
CLINICAL
Patient demographic | Demographics (§ 170.314(a)(3)) | Demographics (§ 170.314(a)(3)) | | Yes
Medical history | | | | Yes
Problem List | Problem List (§ 170.314(a)(5)) | Problem List (§ 170.315(a)(6)) | Removed | Yes
Vitals | Vital Signs, Body Mass Index, and Growth Charts (§ 170.314(a)(4) | | | Yes
Clinical decision support | CDS (§ 170.314(a)(8)) | CDS (§ 170.315(a)(9)) | | Yes, Alerts and Notification; Yes, CDS Falls, Infections, Readmission Prevention, Antipsychotic Reduction, Pressure Ulcer Healing, Preventable Transfer, and Others
Physician order entry | Computerized Provider Order Entry (CPOE) § 170.314(a)(1) | CPOE -- Medications (§ 170.315(a)(1) | | Yes, Physician Orders and Physician Order Recap
| | CPOE -- Laboratory (§ 170.315(a)(2)) | | Yes, Physician Orders and Physician Order Recap
| | CPOE -- Diagnostic Imaging (§ 170.315(a)(3)) | | Yes, Physician Orders and Physician Order Recap
| Optional -- CPOE -- Medications (§ 170.314(a)(18)) | CPOE -- Medications (§ 170.315(a)(1)) | | Yes, Physician Orders and Physician Order Recap
| Optional -- CPOE -- Laboratory (§ 170.314(a)(19)); CPOE -- Laboratory (§ 170.315(a)(2)) | Optional -- CPOE -- Laboratory (§ 170.314(a)(19)); CPOE -- Laboratory (§ 170.315(a)(2)) | | Yes, Lab Orders
| Optional -- CPOE -- Diagnostic Imaging (§ 170.314(a)(20)); CPOE -- Diagnostic Imaging (§ 170.315(a)(3)) | Optional -- CPOE -- Diagnostic Imaging (§ 170.314(a)(20)); CPOE -- Diagnostic Imaging (§ 170.315(a)(3)) | | Yes, Diagnostic Testa and Radiology Orders
| Medication List (§ 170.314(a)(6)) | Medication List (§ 170.315(a)(7)) | Removed | Yes
| Medication Allergy List (§ 170.314(a)(7)) | Medication Allergy List (§ 170.315(a)(8)) | | Yes, Allergy
| Electronic Notes (§ 170.314(a)(9)) | | | Yes, Clinical Notes and Charting
| Drug-Formulary Checks (§ 170.314(a)(10)) | Drug-Formulary and Preferred Drug List Checks (§ 170.315(a)(10)) | Removing January 1, 2022 (sunset of Medicaid Promoting Interoperability program) | Yes, Closed-Loop Medication Verification
| Drug-Drug, Drug-Allergy Interaction Checks (§ 170.314(a)(2)) | Drug-Drug, Drug-Allergy Interaction Checks for CPOE (§ 170.315(a)(4)) | | Yes, Medication Management (Drug-Drug, Drug-Dietary, and Drug-Allergy Interaction)
| Drug-Formulary and Preferred Drug List Checks (§ 170.315(a)(10)) | | | Yes, Medication Management (Drug-Drug, Drug-Dietary, and Drug-Allergy Interaction)
| | Implantable Device List (§ 170.315(a)(14))
| | Social, Psychological, and Behavioral Data (§ 170.315(a)(15)) | | Yes, Assessments and Notes
| Smoking Status (§170.314(a)(11)) | Smoking List (§ 170.315(a)(11)) | Removed
| Image Results (§ 170.314(a)(12)) | | | Yes, Third Party Ancillary Integration including Lab, Radiology (Imaging), and Pharmacy
| Family Health History (§ 170.314(a)(13)) | Family Health History (§ 170.315(a)(12)) | | Yes, Assessments
| Family Health History (§ 170.315(a)(12))
| Patient-Specific Education (§ 170.314(a)(15)) | Patient-Specific Education Resources (§ 170.315(a)(13)) | Removing January 1, 2022 (sunset of Medicaid Promoting Interoperability program)
| Inpatient Setting Only -- Electronic Medication Administration Record (§ 170.314(a)(16)) | See Patient Health Information Capture (§ 170.315(e)(3)) | | Yes, Medication Administration Record and Treatment Administration Record
| Inpatient Setting Only -- Advance Directives (§ 170.314(a)(17) | | | Yes, Advance Directives
| | | | Yes, Assessments (Regulatory and Clinical)
| | | | Yes, Pharmacist Drug Review
| | | | Yes, Controlled Drug Management
| | | | Yes, Dose Reduction Schedules
| | | | Yes, Resident Client Scheduling
| | | | Yes, Staff Scheduling
| | | | Yes, Census
| | | | Yes, Single Medical Record Support
| | | | Yes, Customizable Templates
| | | | Yes, Workflow Management, Alerts and Prompts
| | | | Yes, Incident Management
| | | | Yes, Consent (Informed Consent, Notice and Authorizations)
CARE COORDINATION
| Transitions of Care -- Receive, Display, and Incorporate Transition of Care/Referral Summaries (§ 170.314(b)(1)) | Transitions of Care (§ 170.315(b)(1)) also see (§ 170.315(b)(2) and § 170.315(h)(1) and (2)) | USCDI Update to (§ 170.315(b)(1)) | Yes, Summary of Care Report (Transfer and Discharge); Yes, Summary Report Consults; Yes, Continuity of Care Document (CCD); Yes, Transfer Form
| Electronic Prescribing (§ 170.314(b)(3)) | Electronic Prescribing (§ 170.315(b)(3)) | Updated standard (§ 170.315(b)(3)) | Yes, Electronic Prescribing, Bidirectional
| Clinical Information Reconciliation and Incorporation (§ 170.315(b)(2)) | Clinical Information Reconciliation and Incorporation (§ 170.315(b)(2)) | USCDI Update to (§ 170.315(b)(2)) | Yes, Medication Reconciliation
| Data Portability (§ 170.314(b)(7)) | Data Export (§ 170.315(b)(6)) | Removing 36 months from publication date
| Optional -- Transitions of Care (§ 170.314(b)(8)) | Transitions of Care (§ 170.315(b)(1))
| Optional -- Clinical Information Reconciliation and Incorporation (§ 170.314(b)(9)) | Clinical Information Reconciliation and Incorporation (§ 170.315(b)(2))
| | Common Clinical Data Set Summary Record -- Create (§ 170.315(b)(4)) | Removed
| | Data Segmentation for Privacy -- Send (§ 170.315(b)(7)) | Standards Revision (§ 170.315(b)(7)); Security Tags -- Summary of Care (send) (formerly, DS4P -- Send)
| | Data Segmentation for Privacy -- Receive (§ 170.315(b)(8)) | Standards Revision (§ 170.315(b)(8)); Security Tags -- Summary of Care (receive) (formerly, Ds4P -- Receive)
| | Common Clinical Data Set Summary Record -- Receive (§ 170.315(b)(5)) | Removed
| | Care Plan (§ 170.315(b)(9)) | | Yes, Shareable Plan of Care (including goals and instructions)
CLINICAL QUALITY MEASURES (CQMs)
Capture information for health care quality; Query information for health care quality | CQMs -- Capture and Export (§ 170.314(c)(1)) | CQMs -- Record and Export (§ 170.315(c)(1)) | | Yes, CMS Required Assessment Instruments (used to calculate quality measures)
Integrate information received from other sources | CQMs -- Import and Calculate (§ 170.314(c)(2)) | CQMs -- Import and Calculate (§ 170.315(c)(2))
Exchange information | CQMs -- Electronic Submission (§ 170.314(c)(3)) | CQMs -- Report (§ 170.315(c)(3)) | Standards Revision (§ 170.315(c)(3)); CQMs -- Report | Yes, Electronic Submission of CMS Required Assessment Instruments (used to calculate quality measures)
| | CQMs -- Filter (§ 170.315(c)(4)
Meets certification criteria adopted by Sec.
Meets certification criteria adopted by Sec for Quality Measure domains for eligible professionals (9 measures; 3 domains) and eligible hospitals; (16 measures and 3 domains)
PRIVACY AND SECURITY
| Authentication, Access Control, and Authorization (§ 170.314(d)(1)) | Authentication, Access Control, and Authorization (§ 170.315(d)(1))
| Auditable Events and Tamper-Resistance (§ 170.314(d)(2)) | Auditable Events and Tamper-Resistance (§ 170.315(d)(2))
| Audit Report(s) (§170.314(d)(3)) | Audit Reports (§ 170.315(d)(3)) | Standards Revision (§ 170.315(d)(3))
| Amendments (§ 170.314(d)(4)) | Amendments (§ 170.315(d)(4))
| Automatic Log-Off (§ 170.314(d)(5)) | Automatic Access Time-Out (§ 170.315(d)(5))
| Emergency Access (§ 170.314(d)(6)) | Emergency Access (§ 170.315(d)(6))
| End-User Device Encryption (§ 170.314(d)(7)) | End-User Device Encryption (§ 170.315(d)(7))
| Integrity (§ 170.314(d)(8)) | Integrity (§ 170.315(d)(8))
| Optional -- Accounting of Disclosures (§ 170.314(d)(9)) | Accounting of Disclosures (§ 170.315(d)(11))
| | Trusted Connection (§ 170.315(d)(9))
| | Auditing Actions on Health Information (§ 170.315 (d)(10)) | Standards Revision (§ 170.315(d)(10)); Auditing Actions on Health Information
PATIENT ENGAGEMENT
| View, Download, and Transmit to Third Party (§ 170.314(e)(1)) | View, Download, and Transmit to Third Party (§ 170.315(e)(1)) | USCDI Updates to (§ 170.315(e)(1))
| Ambulatory Setting Only -- Clinical Summary (§ 170.314(e)(2)) | See Common Clinical Data Set Summary Record -- Create (§ 170.315(b)(4)) and Common Clinical Data Set Summary Record -- Receive (§ 170.315(b)(5)) | | Yes, Summary of Care; Yes, Patient Education Resources
| Ambulatory Setting Only -- Secure Messaging (§ 170.314(e)(3)) | Secure Messaging (§ 170.315(e)(2)) | Removing January 1, 2022 (sunset of Medicaid Promoting Interoperability program) | Yes, Secure Text Messaging
| | Patient Health Information Capture (§170.315(e)(3))
| | | | Yes, Global Search Capabilities
PUBLIC HEALTH
| Immunization Information (§ 170.314(f)(1)) | | | Yes, Immunization tracking
| | | | Yes, Infection Surveillance and Management
| Transmission to Immunization Registries (§ 170.314(f)(2)) | Transmission to Immunization Registries (§ 170.315(f)(1))
| Transmission to Public Health Agencies -- Syndromic Surveillance (§ 170.314(f)(3)) | Transmission to Public Health Agencies -- Syndromic Surveillance (§ 170.315(f)(2))
| Optional -- Ambulatory Setting Only -- Transmission to Public Health Agencies -- Syndromic Surveillance (§ 170.314(f)(7))
| Inpatient Setting Only -- Transmission of Reportable Laboratory Tests and Values/Results (§ 170.314(f)(4)) | Transmission to Public Health Agencies -- Reportable Laboratory Tests and Values/Results (§ 170.315(f)(3))
| Optional -- Ambulatory Setting Only -- Cancer Case Information (§ 170.314(f)(5))
| Optional -- Ambulatory Setting Only -- Transmission to Cancer Registries (§ 170.314(f)(6)) | Transmission to Cancer Registries (§ 170.315(f)(4))
| | Transmission to Public Health Agencies -- Electronic Case Reporting (§ 170.315(f)(5) | USCDI Update to 170.315(f)(5) | Yes, Public Health Reporting
| | Transmission to Public Health Agencies -- Antimicrobial Use and Resistance Reporting (§ 170.315(f)(6))
| | Transmission to Public Health Agencies -- Health Care Surveys (§ 170.315(f)(7))
DESIGN AND PERFORMANCE/UTILIZATION
| Automated Numerator Recording (§ 170.314(g)(1)) | Automated Numerator Recording (§ 170.315(g)(1))
| Automated Measure Calculation (§ 170.314(g)(2)) | Automated Measure Calculation (§ 170.315(g)(2))
| Safety-Enhanced Design (§ 170.314(g)(3)) | Safety-Enhanced Design (§ 170.315(g)(3))
| Quality Management System (§ 170.314(g)(4)) | Quality Management System (§ 170.315(g)(4))
| | Accessibility-Centered Design (§ 170.315(g)(5))
| | Consolidated Clinical Document Architecture Creation Performance (§ 170.315(g)(6) | USCDI Update to § 170.315(g)(6)
| | Application Access -- Patient Selection (§ 170.315(g)(7))
| | Application Access -- Data Category Request (§ 170.315(g)(8)) | Removing 24 months from publication date
| | Application Access -- All Data Request (§ 170.315(g)(9)) | USCDI Update to § 170.315(g)(9))
TRANSPORT METHODS AND OTHER PROTOCOLS
| Optional -- Applicability Statement for Secure Health Transport (§ 170.314(h)(1)) | Direct Project (§ 170.315(h)(1)) | | Yes, Send/Receive via ONC’s DIRECT Project
| Transport and XDR/XDM for Direct Messaging (§ 170.314(h)(2)) | Direct Project, Edge Protocol, and XDR/XDM (§ 170.315(h)(2))
| Optional -- SOAP Transport and Security Specification and XDR/XDM for Direct Messaging (§ 170.314(h)(3)
OTHER LTPAC SPECIFIC
| | | | Yes, Safety Monitoring
| | | | Yes, Mobile/Wearable Devices
| | | | Yes, Voice Recognition
| | | | Yes, Digital Camera
| | | | Yes, Information Exchange with HIE
| | | | Yes, Export to Personal Health Record
| | | | Yes, Integrate with Hospital/Discharge/Referral System

Notes:

* Dougherty et al., 2013.

** Comparison of the 2014 Edition & 2015 Edition Certification Criteria (healthit.gov). https://www.healthit.gov/sites/default/files/playbook/pdf/2014-and-2015-edition-comparision.pdf.

*** 2015 Edition Cures Update (healthit.gov). https://www.healthit.gov/topic/information-blocking.

**** LeadingAge Center for Aging Services Technology. (Accessed 9/2021). Technology Selection Tools. https://leadingage.org/technology-selection-tools?_ga=2.69199569.1524041378.1628129418-1365451774.1616156820.