# APPENDIX B DETAILED METHODS

Environmental Scan Methods (Task 1): Based on the three research questions and concept map we worked with a health sciences librarian to construct search strategies related to HIT adoption, EHRs, HIEs, patient populations, quality measurement and reporting, policies, workforce, care coordination, usability, and the LTPAC settings of interest in order to pull full text literature results to review.

Two members of the RTI team reviewed abstracts to identify sources for full-length review. We excluded 132 sources after title and abstract review. Two reviewers independently screened the remaining 119 full-length articles and consulted with another team member to resolve uncertainties. After completing the screening process, we included 68 sources for this report.

The RTI team read the 68 sources meeting our inclusion criteria and categorized them by research question and key themes or topics addressed. The team captured key concepts, findings, and conclusions from the included sources. Additionally, we identified gaps in the literature, topics for discussion with SMEs in Task 2, and potential opportunities for research or policy action based on the literature reviewed.

Limitations of Environmental Scan Methods: First, we searched only two electronic databases and we limited the environmental scan to sources available in English from 2011 to 2021 and pertaining to LTPAC settings in the United States. Some of these limits may have led to the exclusion of relevant publications, but we believe the literature we identified via PubMed, Google Scholar, and manual searches is representative of the available sources published after 2011 and specifically addressing the research questions. Further, these limits increase the applicability of the information to policy makers in the United States concerned with a field that is changing rapidly in terms of technology and accessibility. Second, given the scope and purpose of the environmental scan to identify barriers, facilitators, and potential policy levers, and describe how LTPAC providers are using EHRs, we did not conduct a thorough extraction of study characteristics and outcomes from primary research studies, reports, or program evaluations. The information we captured was descriptive and qualitative to aid in efficiently categorizing and grouping similar concepts from an array of sources. This limits the conclusions we can draw with respect to the availability of evidence regarding provider, patient, and utilization outcomes associated with HIT utilization in LTPAC settings.

SME Interview Analysis Methods (Task 2): To confirm/fill in gaps from the environmental scan findings, gather insights, and discuss policy/research opportunities, RTI engaged SMEs who are experts, leaders, policy analysts, and/or researchers in HIT in LTPAC. RTI interviewed seven SME groups (Researchers, Payers, Provider and Developer Organizations/Technical, Public Health Specialists, HIEs/HINs and two CMS/ONC groups focusing on Interoperability Rule and Value Based Care). The SMEs included, but will not be limited to, academic researchers, state officials, federal officials, and individuals who represent organizations actively engaged in federal and state HIT in LTPAC policy.

SMEs who agreed to participate in an interview were sent a project one pager, final environmental scan, and interview questions. All SME interviews were capped at nine participants and were 60 minutes in length and were recorded solely for notetaking purposes. The research questions varied across the group and discussed current state of HIT adoption in LTPAC settings, barriers, and facilitators to EHRs in LTPAC settings, challenges to LTPACs accessing and sharing data, and potential policy solutions that could promote EHR adoption and use. The one-hour RTI led interviews contained an RTI lead staff member and a primary notetaker. Office of the Assistant Secretary for Planning and Evaluation (ASPE) representatives were included on all SME interview invitations. The lead used a semi-structured interview technique so that the key questions were asked while also allowing space for the interviewer and SME to explore relevant topic areas that may not have been considered when the question guide was developed. SMEs could also follow-up to the interview will written feedback or comments.

RTI synthesized anonymous pieces of the interviews to include in the final report as well as work to include SME quotes in cases where the quotes added further emphasis or context. The final report is to be shared with the SMEs after the conclusion of the project.