# APPENDIX A ELECTRONIC HEALTH RECORD ADOPTION STATISTICS OVER TIME BY SETTING

Tracking LTPAC EHR adoption rates is challenging because there is no unifying definition of EHRs for the LTPAC sector. Therefore, it is difficult to compare adoption rates over time by EHR and setting types and therefore this is a limitation of this study. Data included either full or partial implementation of an EHR system. What is known about HIE is included by provider setting. Several surveys assessed on standard domains: access to a HIN, ability to view, send, receive, and integrate. We describe the findings and surveys on EHR adoption rates by setting below.

Table A-1 EHR Adoption Over Time for Hospitals Participating in CMS Promoting Interoperability Programs (Formerly EHR Incentive Programs)

EHR | Percent
EHR | 2008 | 2009 | 2010 | 2011 | 2012 | 2013 | 2014 | 2015
Basic | 9.4 | 12.2 | 15.6 | 27.6 | 44.4 | 59.4 | 75.5 | 83.8
Certified | | | | 71.9 | 85.2 | 94.0 | 96.9 | 96.0

Source: Adoption of Electronic Health Record Systems among U.S. Non-Federal Acute Care Hospitals: 2008–2015 (healthit.gov) (Henry et al., 2016).

Table A-2 EHR Adoption Over Time for Office-based Physicians

EHR | Percent
EHR | 2008 | 2009 | 2010 | 2011 | 2012 | 2013 | 2014 | 2015 | 2017
Any | 42.0 | 48.3 | 51.0 | 57.0 | 71.8 | 78.4 | 82.8 | 86.9 | 85.9
Basic | 11.8 | 16.9 | 21.8 | 27.9 | 33.9 | 39.6 | 48.1 | 50.5
Certified | | | | | | | 74.0 | 77.9 | 79.7

Source: Office-based Physician Electronic Health Record Adoption (healthit.gov). ONC, 2019. https://www.healthit.gov/data/quickstats/office-based-physician-electronic-health-record-adoption.

Table A-3 EHR Adoption and Interoperability for SNFs and NHs

Year | EHR Adoption Rate, # Facilities Surveyed, (% with EHR)^*^ | Interoperability Domains | Description | Citation
2008 | Range across 4 surveys^**^: 36 – 1,174 (18% – 47%) | Not applicable | ASPE study on the estimate of EHR adoption rate and electronic provider order entry | Richard et al. (2008)
2012 | 472 (48.6%) | Not applicable | Survey of all New York state NHs in 2012 | Abramson et al. (2014)
2013 | 472 (56.3%) | Not applicable | Survey of all New York state NHs in 2013 | Abramson et al. (2014)
2015 | 126^†^ (73%) | HIE across all survey participants:; ■ Engage with a HIN: 31%; ■ View or exchange with hospital: 53%; ■ View only: 24%; ■ Send to hospitals: 16%; Receive electronically from hospital: 27% | NHs in New York conducted by LeadingAge New York Members | LeadingAge (2015)
2016 | 63 (69.8%) | Not applicable | Survey of Arkansas Facilities | Felix et al. (2021)
2016 | 813 (64%) | ■ Find (20%); ■ Send (29%); ■ Receive (23%); ■ Integrate (9%); ■ All 4 domains (7%) | ONC survey of EHR adoption and interoperability in SNFs | Alvarado et al. (2017)
2017 | 1,000 (66%) | ■ Find (27%); ■ Send (41%); ■ Receive (41%); ■ Integrate (18%); ■ All 4 domains (not reported) | ONC survey of EHR adoption and interoperability of SNFs including medication management (reconcile and record), electronic exchange, and methods of exchange | Henry et al. (2018)
2018 | 586 (84%) | ■ Find (32%); ■ Send (22%); ■ Receive (41%); ■ Integrate (12%); ■ All 4 domains (3%) | Survey of EHR adoption and interoperability | Vest et al. (2019)

Notes:

* The definition of an EHR varied between surveys and over time, precluding comparisons between the surveys.

** The separate surveys were conducted among 1,174 NHs, 36 multi-facility long-term care organizations, 68 facilities of various types, and 297 NHs. The surveys were conducted from 2004 to 2007.

† 126 facilities responded, these represent 117 organizations including NHs, HHAs, PACE programs, assisted living, and adult day facilities. Many offered multiple services.

Table A-4 EHR Adoption and Interoperability for HHAs and Hospice

Year | EHR Adoption Rate, # Facilities Surveyed, (% with EHR)^*^ | Interoperability Domains | Description | Citation
2007 | 14,500 (41% all, 37% HHA only, 49% hospice only, 63% HHA and hospice) | Not available | NCHS study on EHR adoption and use in HHA and hospice | Bercovitz et al. (2010)
2007 | 13,100 (44%; includes 28% EHRs and mobile technology and 16% EHR only) | Not available | Study on HHA and hospice use of EHRs and mobile technologies | Bercovitz et al. (2013)
2015 | 126^**^ (68%) | HIE across all survey participants:; ■ Engage with a HIN: 31%; ■ View or Exchange with hospital: 53%; ■ View only: 24%; ■ Send to hospitals: 16%; ■ Receive electronically from hospital: 27% | HHAs in New York conducted by LeadingAge New York members | LeadingAge (2015)
2017 | 1,004 (78%) | ■ Find (41%); ■ Send (52%); ■ Receive (53%); ■ Integrate (36%); ■ All 4 domains (not reported) | ONC survey of EHR adoption and interoperability of HHAs including medication management (reconcile and record), methods of exchange, telehealth, and mobile technology use | Henry et al. (2018)

Notes:

* The definition of an EHR varied between surveys and over time, precluding comparisons between the surveys.

** 126 facilities responded, these represent 117 organizations including NHs, HHAs, PACE programs, assisted living, and adult day facilities. Many offered multiple services.

Table A-5 EHR Adoption and Interoperability for IRFs and LTCHs

Year | EHR Adoption Rate, # Facilities Surveyed, (% with EHR)^*^ | Interoperability Domains | Description | Citation
2009 | IRF, 108 (4%) LTCH, 144 (6%) | Not available | HIT supplement from the American Hospital Association survey of 32 clinical functions of an EHR system | Wolf et al. (2012)

Note:

* The definition of an EHR varied between surveys and over time, precluding comparisons between the surveys.

Table A-6 EHR Adoption for Residential Care Communities and Adult Day Services

Year | EHR Adoption Rate, # Facilities Surveyed, (% with EHR)^*^ | Interoperability Domains | Description | Citation
2012 | 4,319 (20%) Overall, (35.5%) Over 100 beds | Not available | NCHS EHR Use in Residential Care Communities (all types) | Caffrey et al. (2020)
2015 | 126^**^ (46%) | HIE across all survey participants:; ■ Engage with a HIN: 31%; ■ View or Exchange with hospital: 53%; ■ View only: 24%; ■ Send to hospitals: 16%; ■ Receive electronically from hospital: 27% | Assisted Living Facilities in New York conducted by LeadingAge New York members | LeadingAge (2015)
2015 | 126^**^ (56%) | HIE across all survey participants:; ■ Engage with a HIN: 31%; ■ View or Exchange with hospital: 53%; ■ View only: 24%; ■ Send to hospitals: 16%; ■ Receive electronically from hospital: 27% | Managed long-term care plans/PACE programs in New York conducted by LeadingAge New York members | LeadingAge (2015)
2015 | 126^**^ (24%) | HIE across all survey participants:; ■ Engage with a HIN: 31%; ■ View or Exchange with hospital: 53%; ■ View only: 24%; ■ Send to hospitals: 16%; ■ Receive electronically from hospital: 27% | Adult Day Programs in New York conducted by LeadingAge New York members | LeadingAge (2015)
2016 | 4,489 (26%) Overall, (50.0%) Over 100 beds | Not available | NCHS EHR Use in Residential Care Communities (all types) | Caffrey et al (2020)

Notes:

* The definition of an EHR varied between surveys and over time, precluding comparisons between the surveys.

** 126 facilities responded, these represent 117 organizations including NHs, HHAs, PACE programs, assisted living, and adult day facilities. Many offered multiple services.