# Diversity in Caregiving Needs and Networks: Differences by Race-Ethnicity in the Care Older Adults Receive

Issue Brief

## KEY POINTS

- Black men and Black women have lower life expectancy, yet spend more of their late-life years with moderate and significant disabilities than do White people. This is true even for Black people with higher incomes.
- At the same time, Black people with long-term services and supports needs are less likely than White people to have spouses in their care networks.
- Both Hispanic people and Black people are more likely to live with extended family than White people.
- Both Black people and Hispanic people face higher rates of adverse consequences due to unmet long-term services and supports needs than White people, even though they receive greater amounts of unpaid care.

## BACKGROUND

Long-term services and supports (LTSS) includes a range of assistance individuals may need to meet their health or personal needs over an extended period. Most LTSS is not medical care, but rather assistance with the basic personal tasks of everyday life, sometimes called activities of daily living (ADLs), which include such tasks as bathing, dressing, toileting and eating.^1^ Informal care networks are the primary source of LTSS for the older population in the United States. These networks are instrumental to older people’s ability to remain in the community.^2^ If informal care is not available, persons with disabilities may receive paid LTSS or not have their needs met. Health insurance does not cover LTSS costs, and Medicare, the major public insurance program for older Americans, does not cover most LTSS expenses. Medicaid provides LTSS, but it is only available for individuals who meet income and other eligibility requirements.^1^

Research suggests that need for care can vary by race and ethnicity, with Blacks and Hispanics having higher rates of disability requiring assistance than Whites. Whether this higher need can be met through friends and family also varies by race and ethnicity.^2^ The alternative--privately paid care at home--is costly and therefore likely to be unsustainable for many older adults, particularly those who are unmarried or have lower incomes.^2^ This brief uses simulation modeling to add to our understanding of how caregiving needs and networks among older adults vary by race and ethnicity. It shows that the level and timing of the risk of needing long-term services and supports (LTSS) varies widely by race and ethnicity. Black and Hispanic older adults need care sooner and for longer periods than White older adults. They receive more unpaid care, are more likely to co-reside with family, and are more likely to report adverse consequences from unmet LTSS needs than their White counterparts.

## METHODS

Using estimates from the Health and Retirement Study (HRS)^i^ to describe current experiences, and projections from the Dynamic Simulation of Income Model (DYNASIM) to highlight needs over time, we describe differences in care needs, potential family caregiver availability, family care networks, and paid care use, for adults ages 51 and older. We focus on differences by race and Hispanic origin.^ii^

We focus on a more narrow measure of old-age disability, which mirrors the “benefit triggers” for tax-advantaged long-term care insurance policies specified in the Health Insurance Portability and Accountability Act of 1966 (HIPAA). These HIPAA-based criteria focus on more significant disability, identifying people with chronic need for help with two or more ADLs, including incontinence, and adding severe cognitive impairment as a separate criterion. Besides establishing a benchmark for private insurance, the measure has become more common for approximating high need for long-term care services generally and eligibility for Medicaid services specifically, although considerable variation across state programs remains.^2^

DYNASIM is a large-scale dynamic microsimulation model that starts with a nationally representative population and then endeavors to model directly all the underlying processes (disability, care needs, formal and informal care use, eligibility for and use of public programs, unmet need), including their evolving interactions. To dynamically age the population, we use algorithms that generate transition probabilities from year to year. The underlying data for the model includes the HRS (pooled waves 2016 and 2018), the National Health and Aging Trends Study (2015) and the National Health Interview Survey (2018).

## THE DIVERSITY OF LTSS NEEDS

Adults enter their older years with different personal networks, health challenges, and financial resources to address their LTSS needs. As they age, many will encounter a range of difficulties. Some will be able to manage age-related functional decline using assistive devices and supportive services, while others will become physically frail or develop cognitive impairment that will require round-the-clock supervision to remain safe.

Most older Americans can expect to need LTSS as they age,^3,4^ and a growing literature documents that needs and care experiences will vary by race and ethnicity.^5,6,7,8,9,10,11,12,13^ Some of the hypothesized reasons for widely observed disparities in health outcomes, including LTSS needs, are socioeconomic disparities, psychosocial pathways related to discrimination, behavioral norms, comorbidities and genetic factors.^14^ Our analysis found that some difference in LTSS needs by race and ethnic origin vary for men and women (Figure 1).

Non-Hispanic Black (hereafter referred to as Black) people are more likely to experience significant disability. It happens earlier in life, and their mortality is also earlier than Non-Hispanic White (hereafter referred to as White) people. For example, from age 51, a Black man can expect to survive 2.2 fewer total years and 3.1 fewer non-disabled years than a White man. Black people are more likely to experience the onset of significant LTSS needs early in life. This means that they may need to stop work sooner and have less opportunity to accrue retirement wealth that they could use to support paid care or residence in a supportive setting. For example, over 20% of Black people experience onset of significant disability in their fifties and sixties, compared to 11% of White people. Hispanic men and women and White men and women have similar total remaining life expectancy, but White people spend greater shares healthier than Hispanic men and women (see Figure 1).

Figure 1 Remaining Life Expectancy with and without Disability after Age 50 by Sex and Race/Hispanic Origin, People Born between 1960 and 1964

Black men and women spend more of their shorter late-life years with moderate and significant disabilities

NOTES: Sample includes people who survive until at least age 51 and excludes unauthorized immigrants. The analysis defines significant LTSS need as either: (1) a need for assistance with at least 2 ADLs (among eating, toileting, transferring, bathing, dressing, and continence) that cannot be performed due to a condition that is expected to last at least 90 days; or (2) a need for substantial supervision for health and safety threats due to SCI. People are classified as having less significant LTSS need if they report difficulty with at least 1 ADL or instrumental ADL, or if they have mild cognitive impairment. Significant LTSS need can be broken into 2 categories: “ADL disability” indicates a need for assistance with at least 2 ADLs that one is unable to perform due to a condition that is expected to last at least 90 days. “SCI” indicates severe cognitive impairment with a need for substantial supervision due to health or safety threats. People with mild disabilities report difficulty with at least 1 ADL, instrumental ADL, or mild cognitive impairment. People with “no disability” report none of the enumerated disabilities.

FIGURE 1 shows 6 stacked horizontal bars: 3 longer bars for women and 3 shorter bars for men, each by race-ethnicity (Hispanic, non-Hispanic Black, and non-Hispanic White). Each line is made up of 4 segments: the expected number of remaining years of life without disability, the number of year with mild disability, the number of years with limitations in ADLs, and the number of years severely cognitively impaired, with or without limitations in ADLs. Non-Hispanic White women live the longest and have the longest remaining disability-free expected years. Non-Hispanic Black men have the shortest remaining life expectancy and the fewest years without disability.

SOURCE: Urban Institute projections from DYNASIM.

Differences in the likelihood and duration of needing LTSS by race persist even after we take factors like earnings into account. For example, Figure 2 compares remaining life expectancy with and without disabilities from age 51 for Black and White people (Hispanic people not shown) in the lowest, middle, and top family lifetime earnings quintiles. On average, Black people in the bottom earnings quintile can expect to have almost a year less disability-free life than White people in the same group. This gap between White people and Black people in remaining disability-free life expectancy grows to 1.6 years for the middle earnings quintile and 2.9 years for top quintile. Although Black people with higher earnings receive boosts in total and health life expectancy relative to Black people with lower earnings, they can still expect to spend significantly larger shares of late-life with disabilities than White people in each earning quintile. This is consistent with a broader literature on diminished returns (or non-equivalence) of socioeconomic status for Black and Hispanic people.^15,16,17^

Figure 2 Remaining Life Expectancy with and without Disability after Age 50 by Race/Hispanic Origin and Lifetime Earnings Quintile, People Born between 1960 and 1964

Differences in disabled and non-disabled life expectancy by race persist within some earnings groups, with especially large differences in non-disabled life expectancy between Black people and White people in the highest lifetime earnings quintile

NOTES: Sample includes people who survive until at least age 51. Sample excludes people who report Hispanic origin and unauthorized immigrants. “ADL disability” indicates a need for assistance with at least 2 ADLs (among eating, toileting, transferring, bathing, dressing, and continence) that one is unable to perform due to a condition that is expected to last at least 90 days or need. “SCI” indicates severe cognitive impairment for which one requires substantial supervision due to health or safety threats. People with mild disabilities report difficulty with at least 1 ADL, instrumental ADL, or mild cognitive impairment. People with “no disability” report none of the enumerated disabilities. The White and Black categories exclude people of Hispanic origin.

FIGURE 2 contains 3 sets of stacked bars by low, middle and highest income quintiles. Each set compares black to white years of remaining life with no disability, mild disability, activities of daily living disability without severe cognitive impairment, or severe cognitive impairment with or without activities of daily living disability. For each displayed income quintile, White people have longer remaining years of no disability than Black people.

SOURCE: Urban Institute projections from DYNASIM.

## DIVERSITY IN POTENTIAL CARE NETWORKS

Older adults have different networks to which they can turn when they become disabled and need care. As we consider family caregivers’ contributions, it is helpful to distinguish between two separate concepts: one’s potential care network and one’s actual care network. We define one’s potential network based on whether a person has a living spouse or partner or any living children and classify people into four potential care network categories: Spouse and child, spouse only, child only, and others only. A person’s actual care network is made up of the people who provide at least some care over the course of the year. More categories are needed to define actual networks than potential networks, as many care partner combinations are possible (for example, spouse only, spouse and child, child and other, child only, spouse and other, and other only). As we have shown in prior research,^18^ care networks can be quite diverse. Although children and especially spouses tend to be the most intensive caregivers, all types of friends and family--including siblings, nieces and nephews, in-laws, ex-spouses, and grandchildren--often step in to help people with LTSS needs.

One of the most common sources of care are spouses. Spouses tended to provide more hours of care than other care partners.^18^ Yet the presence of a potential spousal caregiver varies by disability status, race and Hispanic origin, and sex of the care recipient. Among those ages 51 and older, people with significant LTSS needs are less likely than other people to have a spouse in their potential network.^iii^ This largely reflects the higher average age for people with disabilities; with age, more once-married older adults become widowed. Also, Black people are less likely than White and Hispanic people to have a spouse in their potential caregiving network, in part due to lower marriage rates and higher rates of widow(er)hood among those who marry.^2^

Figure 3 Distribution of Potential Care Networks by Race-Hispanic Origin, People with Significant LTSS Needs

Black people with significant LTSS needs are less likely to have spouses in their care networks

NOTES: The analysis defines significant LTSS need as either: (1) a need for assistance with at least 2 ADLs (among eating, toileting, transferring, bathing, dressing, and continence) that cannot be performed due to a condition that is expected to last at least 90 days; or (2) a need for substantial supervision for health and safety threats due to SCI. The term "spouse" includes legal spouses and also unmarried co-residents who identify as partners. The White and Black categories exclude people of Hispanic origin.

FIGURE 3 contains 3 stacked bars by race-ethnicity (Hispanic, non-Hispanic Black, and non-Hispanic White). Each bar contains 4 segments reflecting potential care networks: spouse and child, spouse only, child only, and other only. For non-Hispanic Black people, the segment for others only is longer and the segments for spouse only and spouse and child are shorter than for the other 2 groups.

SOURCE: Urban Institute estimates from 2016 HRS. Sample is people age 51 and older.

## DIVERSITY IN ACTUAL CARE NETWORKS

People with spouses, children or other potential caregivers may not necessarily receive care from them and may instead, for example, rely on paid help. However, differences in the potential network of caregivers translate into observed differences in actual caregiving networks.

People who have significant LTSS needs and are White or Hispanic are more likely to receive spousal care than people who are Black (Figure 4). Black people with significant needs are more likely to rely on children as caregivers and others exclusively compared to White people, and to a lesser extent Hispanic people.

Figure 4 Distribution of Actual Care Networks by Race-Hispanic Origin, People with Significant LTSS Needs

Black people are less likely to have a spouse and more likely to have no care providers or people other than a spouse in their care provider networks

NOTES: Sample includes people ages 51 and older reporting significant LTSS needs. "Significant LTSS needs" indicates a need for assistance with at least 2 ADLs (among eating, toileting, transferring, bathing, dressing, and continence) that one is unable to perform due to a condition that is expected to last at least 90 days or need for substantial supervision for health and safety threats due to SCI. People with less severe disabilities report difficulty with at least 1 ADL, instrumental ADL, or mild cognitive impairment. The term "spouse" includes legal spouses and also unmarried co-residents who identify as partners. The White and Black categories exclude people of Hispanic origin.

FIGURE 4 contains 3 stacked bars by race-ethnicity (Hispanic, non-Hispanic Black, and non-Hispanic White). Each bar contains 6 segments reflecting actual care networks: spouse only or spouse and other, spouse and child with or without others, child only, child and other, other only, and none. For non-Hispanic Black people, the segment for others only and no care are longer and the segments for spouse only and spouse and child are shorter than for the other 2 groups.

SOURCE: Urban Institute estimates from 2016 HRS.

## DIVERSITY IN CO-RESIDENCE

An important component of care for older adults with disabilities is co-residence. For many people, moving in with family is an economical care option. Financial and caregiving reasons are most often cited as the reason for co-residence.^19^ Variations in socioeconomic status, immigration, marriage patterns and health status are reasons that Blacks and Hispanics are more likely to co-reside. Other reasons may include feelings of altruism, social norms and obligations which vary among ethnic groups.^20^ Among older people who receive some care, Black, and especially Hispanic, people are more likely than White people to share a residence with someone other than a spouse and receive only unpaid care (Figure 5). Importantly, co-residence varies by race and Hispanic origin at all ages, not just among older adults.^iv,21,22^

Figure 5 Distribution of Actual Joint Care Choices among People Receiving Care, by Race-Ethnicity

Both Hispanic people and Black people are more likely to live with extended family

NOTES: Sample includes people ages 51 and older reporting use of care. "Alone" indicates that a person is living by him/herself or only with a spouse or partner. "Shared" indicates that a person is living with at least 1 person other than a spouse/partner. The White and Black categories exclude people of Hispanic origin.

FIGURE 5 contains 3 stacked bars by race-ethnicity (Hispanic, non-Hispanic Black, and non-Hispanic White). Each bar contains 6 segments reflecting different types of care arrangements: just paid care and sharing housing with a person other than spouse; just paid care and living alone or with a spouse only; just unpaid care and sharing housing with a person other than spouse; just unpaid care and living alone or with a spouse only; both paid and unpaid care and sharing housing with a person other than spouse; both paid care and unpaid care and living alone or with a spouse only. People who are non-Hispanic White are more likely than others to be in group 4--receiving just unpaid care and living alone or with a spouse only. People who are Hispanic or non-Hispanic Black are more likely than others to be in group 3--just unpaid care and sharing housing with a person other than spouse.

SOURCE: Urban Institute estimates from 2016 HRS.

## INTENSITY OF CARE RECEIVED

Figure 6 Average Hours of Unpaid Care by Relationship, Disability Severity, and Race-Ethnicity

Although the average amount of unpaid care hours is similar across groups, their compositions differs, with Black people receiving more care from people other than a spouse or child than others

NOTES: "Significant LTSS need" indicates a need for assistance with at least 2 ADLs (among eating, toileting, transferring, bathing, dressing, and continence) that one is unable to perform due to a condition that is expected to last at least 90 days or need for substantial supervision for health and safety threats due to SCI. People with less significant LTSS needs report difficulty with at least 1 ADL, instrumental ADL, or mild cognitive impairment. The White and Black categories exclude people of Hispanic origin.

FIGURE 6 shows 9 stacked 3 each by disability status (everyone, people with at least 1 impairment, and people with severe disabilities) and race-ethnicity (Hispanic, non-Hispanic Black, and non-Hispanic White). Each line is made up of 3 segments reflecting care hours from: spouses, children, or other people. Amount of care received increases dramatically with presence and severity of disability. People who are non-Hispanic Black receive the most care in all 3 groups, and people who are non-Hispanic White the least. Composition of care also differs, most notably due to the greater amount of care that people who are non-Hispanic Black receive from people other than spouses and children.

SOURCE: Urban Institute estimates from 2016 and 2018 HRS.

The amount of care that older adults receive depends on the severity of their functional limitations and the composition of their networks (Figure 6). Regardless of disability level, estimates from the HRS suggest that Black and Hispanic older adults receive more hours of unpaid care than White older adults. One likely contributor to these differences is that people who are White are more likely to use assisted living than others.^23^ Levels of care provided by children and people other than spouses and children (e.g., siblings, grandchildren) are higher, especially for Black older adults.

## ADVERSE CONSEQUENCES OF UNMET NEED

Black people and people of Hispanic origin are more likely to report adverse consequences from unmet need, especially relative to White people at younger ages (Figure 7). Although caregivers often devote extensive energies to helping older adults with disabilities, many older adults with disabilities experience adverse consequences because not all of their LTSS needs are met. In defining adverse consequences, we include such events as going without a hot meal, clean laundry, or shopping for needed items, being unable to go outside the home, get out of bed, bathe, or dress, or having a toilet accident. Even after accounting for age, the likelihood of experiencing adverse consequences differs depending on race/Hispanic origin.

Figure 7 Share with Adverse Consequences due to Unmet LTSS Needs by Age and Race-Hispanic Origin

Black people and Hispanic people are more likely than White people to experience adverse consequences due to unmet LTSS need

NOTES: Sample includes people ages 65 and older, pooled person years 2015–2024. Adverse consequences are defined as having difficulty performing any of 12 household, mobility, and self-care activities without human assistance even with any assistive technology used, or receiving human assistance. The White and Black categories exclude people of Hispanic origin.

FIGURE 7 shows 15 bars: 3 each by race-ethnicity (Hispanic, non-Hispanic Black, and non-Hispanic White) for five ranges (65-69, 70-79, 80-89, 90+, and then all people ages 65 and older). The chart reveals that presence of adverse consequences from unmet needs increases with age. For all groups, the share with adverse consequences is about 4 times higher at age 90 than age 65-69. In all age ranges, people who are non-Hispanic White are the least likely to report adverse consequences.

SOURCE: Urban Institute estimates from DYNASIM.

## DISCUSSION

As the large cohorts of baby boomers reach ages when LTSS needs grow rapidly, their family caregivers may face increasingly difficult choices about how to combine paid and unpaid care. These choices differ across racial/ethnic groups, with people who are Black and Hispanic needing care earlier and for longer periods. Care networks, care providers, strategies for care delivery, and care outcomes vary by race/Hispanic origin. While Black people and Hispanic people have higher LTSS needs and receive more unpaid care, their care networks may have more challenges in fully meeting their needs relative to White people. Black people and Hispanic people are more likely to co-reside and rely on children than others, and more likely to report unmet LTSS needs.

In three companion briefs, we discuss the economic value of the unpaid care that family and friends provide,^24^ how care use changes over the course of a disability,^25^ and how care needs and networks are likely to change in coming decades.^26^

## ADDITIONAL METHODOLOGICAL INFORMATION

For information about DYNASIM, see Favreault and Johnson.^3^ The specific release of the model that we use is runid 981, which incorporates economic and demographic assumptions from an interim baseline produced by Social Security’s Office of the Chief Actuary.^24^

## ENDNOTES

i The HRS is a nationally representative longitudinal study of adults ages 51 and older. It oversamples Black and Hispanic people.

ii Our estimates by race and ethnicity focus on three groups: White people, Black people, and Hispanic people of any race. The analyses here omit non-Hispanic people of other races, including Asian-Americans, Pacific Islanders, Native Americans, Alaska Natives, and others. We do not present estimates here due to data limitations within the HRS.

iii We define significant LTSS need as a level of impairment consistent with the definition specified in the Health Insurance Portability and Accountability Act of 1996 for long-term care insurance plans that qualify for tax preferences. Specifically, one must need assistance with at least two activities of daily living (ADLs) among eating, toileting, transferring, bathing, dressing, and continence that one is unable to perform due to a condition that is expected to last at least 90 days or need substantial supervision for health and safety threats due to severe cognitive impairment (SCI). This disability threshold does not count limitations in performing ADLs that can be resolved with special equipment (e.g., wheelchairs, walkers, handrails, ramps, catheters, and related devices).

iv For example, Britton (2013) describes significant differences by race in prevalence of living with parents during young adulthood, with non-White young adults more likely to live with parents through their twenties, more likely to return to the parental home after college, and less likely to leave after returning. He finds that differences are largely explained by marital status and socioeconomic factors, and less by differences in attitudes. Reyes, Schoeni, and Choi (2020) point to differences in co-residence with mother and geographic distance to mothers by race and ethnicity, finding that they are largely driven by demographic factors, like marital status and immigration, and socioeconomic status, though health is also a factor.

## REFERENCES

1 Johnson R.W., Dey J. (2022). Long-Term Services and Supports for Older Americans: Risks and Financing, 2022 (Research Brief). Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. https://aspe.hhs.gov/sites/default/files/documents/8f976f28f7d0dae32d98c7fff8f057f3/ltss-risks-financing-2022.pdf.
2 Spillman B.C., Allen E.H., Favreault M. (2020). Informal Caregiver Supply and Demographic Changes: Review of the Literature. Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. https://aspe.hhs.gov/reports/informal-caregiver-supply-demographic-changes-review-literature-0.
3 Favreault M.M., Johnson R.W. (2020). Projections of Risk of Needing Long-Term Services and Supports at Ages 65 and Older. Washington, DC: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation.
4 Johnson R. (2019). What Is the Lifetime Risk of Needing and Receiving Long-Term Services and Supports? Washington, DC: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation. https://aspe.hhs.gov/basic-report/what-lifetime-risk-needing-and-receiving-long-term-services-and-supports.
5 Choi H., Schoeni R.F., Martin L.G., Langa K.M. (2018). Trends in the Prevalence and Disparity in Cognitive Limitations of Americans 55–69 Years Old. Journals of Gerontology: Social Sciences, 73(S1): S29–S37. doi:10.1093/geronb/gbx155.
6 Farina M.P., Hayward M.D., Kim J.K., Crimmins E.M. (2019). Racial and Educational Disparities in Dementia and Dementia-Free Life Expectancy. Journals of Gerontology: Social Sciences. Advance Access.
7 Freedman V.A., Kasper J.D., Spillman B.C., Plassman B.L. (2018). Short-Term Changes in the Prevalence of Probable Dementia: An Analysis of the 2011–2015 National Health and Aging Trends Study. Journals of Gerontology: Series B, 73(S1): S48–S56. doi.org/10.1093/geronb/gbx144.
8 Garcia M.A., Downer B., Chiu C.-T., Saenz J.L., Rote S., Wong R. 2017. Racial/Ethnic and Nativity Differences in Cognitive Life Expectancies among Older Adults in the United States. Gerontologist, 59(2).
9 Gilsanz P., Corrada M.M., Kawas C.H., Mayeda E.R., Glymour M.M., Quesenberry C.P. Jr., Lee C., Whitmer R.A. (2019). Incidence of Dementia after Age 90 in a Multiracial Cohort. Alzheimer’s & Dementia. doi.org/10.1016/j.jalz.2018.12.006.
10 Matthews K.A., Xu W., Gaglioti A.H., Holt J.B., Croft J.B., Mack D., McGuire L.C. (2019). Racial and Ethnic Estimates of Alzheimer’s Disease and Related Dementias in the United States (2015–2060) in Adults Aged >65 Years. Alzheimer’s & Dementia, 15(1): 17–24. doi.org/10.1016/j.jalz.2018.06.3063.
11 Mayeda E.R., Glymour M.M., Quesenberry C.P, Whitmer R.A. (2016). Inequalities in Dementia Incidence between Six Racial and Ethnic Groups over 14 Years. Alzheimer’s & Dementia, 12(3): 216–224. doi:10.1016/j.jalz.2015.12.007.
12 Mayeda E.R., Glymour M.M., Quesenberry C.P., Johnson J.K., Pérez-Stable E.J., Whitmer R.A. (2017). Survival after Dementia Diagnosis in Five Racial/Ethnic Groups. Alzheimer’s & Dementia, 13: 761–769.
13 Reuser M., Willekens F.J., Bonneux L. (2011). Higher Education Delays and Shortens Cognitive Impairment. A Multistate Life Table Analysis of the US Health and Retirement Study. European Journal of Epidemiology, 26: 395–403. doi:10.1007/s10654-011-9553-x.21337033
14 Mayeda E.R., Glymour M.M., Quesenberry C.P., Whitmer R.A. (2016). Inequalities in Dementia Incidence Between Six Racial and Ethnic Groups over 14 years. Alzheimers Dement, 12(3): 216–24. doi:10.1016/j.jalz.2015.12.007. Epub 2016 Feb 11. PMID: 26874595; PMCID: PMC4969071.26874595
15 Spillman B.C., Favreault M., Allen E. (2020). Family Structures and Support Strategies in the Older Population: Implications for Baby Boomers (Issue Brief). Washington, DC: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation. https://aspe.hhs.gov/system/files/pdf/264806/SnapshotIB.pdf.
16 Assari S., Bazargan M. (2020). .Educational Attainment Better Reduces Disability for Non-Hispanic than Hispanic Americans. European Journal of Investigation in Health, Psychology, & Education, 10: 10–17. doi:10.3390/ejihpe10010002.32089977
17 Assari S. (2018). Health Disparities due to Diminished Return among Black Americans: Public Policy Solutions. Social Issues & Policy Review, 12(1): 112–145.
18 Bell C.N., Sacks T.K., Thomas Tobin C.S., Thorpe R.J. Jr. (2020). Racial Non-equivalence of Socioeconomic Status and Self-rated Health among African Americans and Whites. Population Health, 10. doi.org/10.1016/j.ssmph.2020.100561.
19 Pew Research Center. (2022). Financial Issues Top the List of Reasons U.S. Adults Live in Multigenerational Homes. https://www.pewresearch.org/social-trends/wp-content/uploads/sites/3/2022/03/PSDT_03.24.22_multigenerationalhouseholds.report.pdf.
20 Keene J., Batson C. (2010). Sociology Compass. Under One Roof: A Review of Research on Intergenerational Coresidence and Multigenerational Households in the United States. Sociology Compass, 4(8): 642–657. doi:org/10.1111/j.1751-9020.2010.00306.x.
21 Britton M.L. (2013). Race/Ethnicity, Attitudes, and Living with Parents During Young Adulthood. Journal of Marriage & Family, 75(4): 995–1013.
22 Reyes A., Schoeni R.F., Choi H. (2020). Race/ethnic Differences in Spatial Distance between Adult Children and their Mothers. Journal of Marriage & Family, 82(2): 810–821.33414564
23 Freedman V.A., Spillman B.C. (2014). The Residential Continuum from Home to Nursing Home: Size, Characteristics and Unmet Needs of Older Adults. Journals of Gerontology, Series B: Psychological Sciences & Social Sciences, 69(7), S42–S50. doi:10.1093/geronb/gbu120.25342822
24 Favreault M., Johnson R., Dey J., Anderson L., Lamont H., Marton W. (2021). The Economic Value of Unpaid Care Provided to Older Adults with Needs for Long-Term Services and Supports (Issue Brief). Washington, DC: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation.
25 Favreault M., Dey J., Anderson L., Lamont H., Marton W. (2021). Change in Caregiving Networks over the Course of Disability (Issue Brief). Washington, DC: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation.
26 Favreault M., Dey J., Anderson L., Lamont H., Marton W. (2021). Future Change in Caregiving Networks: How Family Caregivers and Direct Care Workers Support Older Adults Now and in the Future (Issue Brief). Washington, DC: U.S. Department of Health and Human Services, Office of the Assistant Secretary for Planning and Evaluation.