# REFERENCES

1 Ciccarone D. The rise of illicit fentanyls, stimulants and the fourth wave of the opioid overdose crisis. Curr Opin Psychiatry. 2021; 34(4): 344–50. doi: 10.1097/yco.0000000000000717. PubMed PMID: 33965972; PubMed Central PMCID: PMC8154745.33965972
2 Petry NM. Contingency management: What it is and why psychiatrists should want to use it. Psychiatrist. 2011; 35(5): 161–3. doi: 10.1192/pb.bp.110.031831. PubMed PMID: 22558006; PubMed Central PMCID: PMC3083448.22558006
3 Lussier JP, Heil SH, Mongeon JA, Badger GJ, Higgins ST. A meta-analysis of voucher-based reinforcement therapy for substance use disorders. Addiction. 2006; 101(2): 192–203. doi: 10.1111/j.1360-0443.2006.01311.x. PubMed PMID: 16445548.16445548
4 Ronsley C, Nolan S, Knight R, Hayashi K, Klimas J, Walley A, Treatment of stimulant use disorder: A systematic review of reviews. PloS one. 2020; 15(6): e0234809.32555667
5 Oluwoye O, Kriegel L, Alcover KC, McPherson S, McDonell MG, Roll JM. The dissemination and implementation of contingency management for substance use disorders: A systematic review. Psychol Addict Behav. 2020; 34(1): 99–110. Epub 20190701. doi: 10.1037/adb0000487. PubMed PMID: 31259569; PubMed Central PMCID: PMC6938576.31259569
6 Becker SJ, DiClemente-Bosco K, Rash CJ, Garner BR. Effective, but underused: Lessons learned implementing contingency management in real-world practice settings in the United States. Preventive Medicine. 2023: 107594. doi: 10.1016/j.ypmed.2023.107594.37385413
7 Carroll KM. Lost in translation? Moving contingency management and cognitive behavioral therapy into clinical practice. Annals of the New York Academy of Sciences. 2014; 1327(1): 94–111. doi: 10.1111/nyas.12501.25204847
8 McGovern MP, Fox TS, Xie H, Drake RE. A survey of clinical practices and readiness to adopt evidence-based practices: Dissemination research in an addiction treatment system. Journal of Substance Abuse Treatment. 2004; 26(4): 305–12. doi: 10.1016/j.jsat.2004.03.003.15182895
9 Rawson RA, Erath TG, Chalk M, Clark HW, McDaid C, Wattenberg SA, Contingency management for stimulant use disorder: Progress, challenges, and recommendations. J Ambul Care Manage. 2023; 46(2): 152–9. Epub 20230203. doi: 10.1097/jac.0000000000000450. PubMed PMID: 36745163.36745163
10 Benishek LA, Kirby KC, Dugosh KL, Padovano A. Beliefs about the empirical support of drug abuse treatment interventions: A survey of outpatient treatment providers. Drug and Alcohol Dependence. 2010; 107(2): 202–8. doi: 10.1016/j.drugalcdep.2009.10.013.19959299
11 Bride BE, Abraham AJ, Roman PM. Diffusion of contingency management and attitudes regarding its effectiveness and acceptability. Substance Abuse. 2010; 31(3): 127–35. doi: 10.1080/08897077.2010.495310. PubMed PMID: 20687001.20687001
12 Kirby KC, Benishek LA, Dugosh KL, Kerwin ME. Substance abuse treatment providers’ beliefs and objections regarding contingency management: Implications for dissemination. Drug and Alcohol Dependence. 2006; 85(1): 19–27. doi: 10.1016/j.drugalcdep.2006.03.010.16650657
13 Randall J. Challenges and possible solutions for implementing contingency management for adolescent substance use disorder in community-based settings. Journal of Child & Adolescent Substance Abuse. 2017; 26(4): 332–7. doi: 10.1080/1067828X.2017.1306470.
14 Prendergast M, Podus D, Finney J, Greenwell L, Roll J. Contingency management for treatment of substance use disorders: A meta-analysis. Addiction. 2006; 101(11): 1546–60. doi: 10.1111/j.1360-0443.2006.01581.x. PubMed PMID: 17034434.17034434
15 Centers for Disease Control and Prevention (CDC). Provisional Data Shows U.S. Drug Overdose Deaths Top 100,000 in 2022–2023 [updated May 18, 2023]. Available from: https://blogs.cdc.gov/nchs/2023/05/18/7365/.
16 O'Donnell J, Gladden RM, Mattson CL, Hunter CT, Davis NL. Vital signs: Characteristics of drug overdose deaths involving opioids and stimulants -- 24 states and the District of Columbia, January-June 2019. MMWR Morb Mortal Wkly Rep. 2020; 69(35): 1189–97. Epub 20200904. doi: 10.15585/mmwr.mm6935a1. PubMed PMID: 32881854; PubMed Central PMCID: PMC7470457.32881854
17 Ahmad FB CJ, Rossen LM, Sutton P. Provisional Drug Overdose Death Counts: National Center for Health Statistics; 2023 [cited 2023 July 24]. Available from: https://www.cdc.gov/nchs/nvss/vsrr/drug-overdose-data.htm.
18 U.S. Overdose Deaths In 2021 Increased Half as Much as in 2020 -- But Are Still Up 15% [Internet]. 2022; May 11, 2022 [cited July 24, 2023]. Available from: https://www.cdc.gov/nchs/pressroom/nchs_press_releases/2022/202205.htm.
19 Centers for Disease Control and Prevention (CDC). Stimulant Guide 2023 [updated February 24, 2023; cited 2023 July 24]. Available from: https://www.cdc.gov/drugoverdose/featured-topics/stimulant-guide.html.
20 Substance Abuse and Mental Health Services Administration (SAMHSA). Treatment of Stimulant Use Disorders. Rockville, MD: Substance Abuse and Mental Health Services Administration, 2020 PEP20–06-01–001.
21 Rash CJ, DePhilippis D. Considerations for implementing contingency management in substance abuse treatment clinics: The veterans affairs initiative as a model. Perspectives on Behavior Science. 2019; 42(3): 479–99. doi: 10.1007/s40614-019-00204-3.31976446
22 DePhilippis D, Petry NM, Bonn-Miller MO, Rosenbach SB, McKay JR. The national implementation of contingency management (CM) in the Department of Veterans Affairs: Attendance at CM sessions and substance use outcomes. Drug & Alcohol Dependence. 2018; 185: 367–73. doi: 10.1016/j.drugalcdep.2017.12.020.29524874
23 Ruan H, Bullock CL, Reger GM. Implementation of contingency management at a large VA addiction treatment center. Psychiatr Serv. 2017; 68(12): 1207–9. Epub 20170915. doi: 10.1176/appi.ps.201700242. PubMed PMID: 28945178.28945178
24 Petry NM, DePhilippis D, Rash CJ, Drapkin M, McKay JR. Nationwide dissemination of contingency management: The Veterans Administration initiative. Am J Addict. 2014; 23(3): 205–10. doi: 10.1111/j.1521-0391.2014.12092.x. PubMed PMID: 24724876; PubMed Central PMCID: PMC3986725.24724876
25 Rash CJ, DePhilippis D, McKay JR, Drapkin M, Petry NM. Training workshops positively impact beliefs about contingency management in a nationwide dissemination effort. Journal of Substance Abuse Treatment. 2013; 45(3): 306–12. doi: 10.1016/j.jsat.2013.03.003.23856601
26 U.S. Department of Veterans Affairs. VAntage Point. 2019. Available from: https://blogs.va.gov/VAntage/64870/how-va-uses-contingency-management-help-veterans-stay-drug-free/.
27 Hernández-Delgado H. Treating Stimulant Use Disorder: CalAIM’s Contingency Management Pilot. 2022 May 2022. Report No.: N/A.
28 Administration for Children and Families. Community Reinforcement Approach + Vouchers: Title IV-E Prevention Services Clearinghouse; 2022 [updated March 2022; cited 2023 July 24]. Available from: https://preventionservices.acf.hhs.gov/programs/349/show.
29 Budney AJ. A Community Reinforcement Plus Vouchers Approach: Treating Cocaine Addiction. National Institute on Drug Abuse; 1998.
30 National Institute on Drug Abuse (NIDA). Addiction and Health 2020 [updated July 2020; cited 2023 July 24]. Available from: https://nida.nih.gov/publications/drugs-brains-behavior-science-addiction/addiction-health.
31 Dembosky A. To Combat Meth, California Will Try A Bold Treatment: Pay Drug Users To Stop Using. NPR [Internet]. 2021. Available from: https://www.npr.org/sections/health-shots/2021/09/30/1040412804/to-combat-meth-california-will-try-a-bold-treatment-pay-drug-users-to-stop-using.
32 Goodnough A. This addiction treatment works. Why is it so underused? New York Times [Internet]. 2020. Available from: https://www.nytimes.com/2020/10/27/health/meth-addiction-treatment.html.
33 Center for Health Law and Policy Innovation. Letter to ONDCP on Contingency Management Policy Barriers 2022. Available from: https://www.healthlawlab.org/wp-content/uploads/2023/01/Letter-to-ONDCP-on-Contingency-Management-Policy-Barriers-2022.pdf.
34 Higgins ST, Heil SH, Lussier JP. Clinical implications of reinforcement as a determinant of substance use disorders. Annu Rev Psychol. 2004; 55: 431–61.14744222
35 Petry NM, Alessi SM, Olmstead TA, Rash CJ, Zajac K. Contingency management treatment for substance use disorders: How far has it come, and where does it need to go? Psychology of Addictive Behaviors. 2017; 31(8): 897.28639812
36 Leickly E, Skalisky J, Angelo FA, Srebnik D, McPherson S, Roll JM, Perspectives on a contingency management intervention for alcohol use among consumers with serious mental illness. Psychiatr Rehabil J. 2019; 42(1): 26–31. Epub 20181126. doi: 10.1037/prj0000330. PubMed PMID: 30475006; PubMed Central PMCID: PMC6506435.30475006
37 Rash CJ. Implementing an evidence-based prize contingency management protocol for stimulant use. J Subst Use Addict Treat. 2023; 151: 209079. Epub 20230524. doi: 10.1016/j.josat.2023.209079. PubMed PMID: 37230390; PubMed Central PMCID: PMC10330855.37230390
38 Petry NM. Contingency management for substance abuse treatment: A guide to implementing this evidence-based practice: Routledge; 2013.
39 Petry NM. A comprehensive guide to the application of contingency management procedures in clinical settings. Drug Alcohol Depend. 2000;58(1–2):9–25. doi: 10.1016/s0376-8716(99)00071-x. PubMed PMID: 10669051.10669051
40 Hartzler B, Jackson TR, Jones BE, Beadnell B, Calsyn DA. Disseminating contingency management: impacts of staff training and implementation at an opiate treatment program. J Subst Abuse Treat. 2014;46(4):429–38. Epub 20131221. doi: 10.1016/j.jsat.2013.12.007. PubMed PMID: 24462242; PubMed Central PMCID: PMC3966904.24462242
41 Dutra L, Stathopoulou G, Basden SL, Leyro TM, Powers MB, Otto MW. A meta-analytic review of psychosocial interventions for substance use disorders. American Journal of Psychiatry. 2008;165(2):179–87.18198270
42 Benishek LA, Dugosh KL, Kirby KC, Matejkowski J, Clements NT, Seymour BL, Prize-based contingency management for the treatment of substance abusers: A meta-analysis. Addiction. 2014; 109(9): 1426–36. Epub 20140523. doi: 10.1111/add.12589. PubMed PMID: 24750232; PubMed Central PMCID: PMC4203362.24750232
43 Petry NM, Alessi SM, Hanson T, Sierra S. Randomized trial of contingent prizes versus vouchers in cocaine-using methadone patients. J Consult Clin Psychol. 2007; 75(6): 983–91. doi: 10.1037/0022-006X.75.6.983. PubMed PMID: 18085914.18085914
44 Petry NM, Alessi SM, Marx J, Austin M, Tardif M. Vouchers versus prizes: Contingency management treatment of substance abusers in community settings. J Consult Clin Psychol. 2005; 73(6): 1005–14. doi: 10.1037/0022-006X.73.6.1005. PubMed PMID: 16392974.16392974
45 De Crescenzo F, Ciabattini M, D'Alo GL, De Giorgi R, Del Giovane C, Cassar C, Comparative efficacy and acceptability of psychosocial interventions for individuals with cocaine and amphetamine addiction: A systematic review and network meta-analysis. PLoS Med. 2018; 15(12): e1002715. Epub 20181226. doi: 10.1371/journal.pmed.1002715. PubMed PMID: 30586362; PubMed Central PMCID: PMC6306153.30586362
46 Schierenberg A, van Amsterdam J, van den Brink W, Goudriaan AE. Efficacy of contingency management for cocaine dependence treatment: A review of the evidence. Curr Drug Abuse Rev. 2012; 5(4): 320–31. doi: 10.2174/1874473711205040006. PubMed PMID: 23244344.23244344
47 Cahill K, Hartmann‐Boyce J, Perera R. Incentives for smoking cessation. Cochrane Database of Systematic Reviews. 2015(5). doi: 10.1002/14651858.CD004307.pub5. PubMed PMID: CD004307.
48 Notley C, Gentry S, Livingstone-Banks J, Bauld L, Perera R, Hartmann-Boyce J. Incentives for smoking cessation. Cochrane Database Syst Rev. 2019; 7: CD004307. Epub 20190717. doi: 10.1002/14651858.CD004307.pub6. PubMed PMID: 31313293; PubMed Central PMCID: PMC6635501.31313293
49 Ginley MK, Pfund RA, Rash CJ, Zajac K. Long-term efficacy of contingency management treatment based on objective indicators of abstinence from illicit substance use up to 1 year following treatment: A meta-analysis. J Consult Clin Psychol. 2021; 89(1): 58–71. doi: 10.1037/ccp0000552. PubMed PMID: 33507776; PubMed Central PMCID: PMC8034391.33507776
50 Sabioni P, Le Foll B. Psychosocial and pharmacological interventions for the treatment of cannabis use disorder. F1000Res. 2018; 7: 173. Epub 20180212. doi: 10.12688/f1000research.11191.1. PubMed PMID: 29497498; PubMed Central PMCID: PMC5811668.29497498
51 Alessi SM, Petry NM. Smoking reductions and increased self-efficacy in a randomized controlled trial of smoking abstinence-contingent incentives in residential substance abuse treatment patients. Nicotine Tob Res. 2014; 16(11): 1436–45. Epub 20140616. doi: 10.1093/ntr/ntu095. PubMed PMID: 24935755; PubMed Central PMCID: PMC4271087.24935755
52 Carroll KM, Nich C, Petry NM, Eagan DA, Shi JM, Ball SA. A randomized factorial trial of disulfiram and contingency management to enhance cognitive behavioral therapy for cocaine dependence. Drug Alcohol Depend. 2016; 160: 135–42. Epub 20160113. doi: 10.1016/j.drugalcdep.2015.12.036. PubMed PMID: 26817621; PubMed Central PMCID: PMC4767616.26817621
53 Kadden RM, Litt MD, Kabela-Cormier E, Petry NM. Abstinence rates following behavioral treatments for marijuana dependence. Addict Behav. 2007; 32(6): 1220–36. Epub 20060922. doi: 10.1016/j.addbeh.2006.08.009. PubMed PMID: 16996224; PubMed Central PMCID: PMC1903379.16996224
54 Rawson RA, McCann MJ, Flammino F, Shoptaw S, Miotto K, Reiber C, A comparison of contingency management and cognitive-behavioral approaches for stimulant-dependent individuals. Addiction. 2006; 101(2): 267–74. doi: 10.1111/j.1360-0443.2006.01312.x. PubMed PMID: 16445555.16445555
55 Shoptaw S, Reback CJ, Peck JA, Yang X, Rotheram-Fuller E, Larkins S, Behavioral treatment approaches for methamphetamine dependence and HIV-related sexual risk behaviors among urban gay and bisexual men. Drug Alcohol Depend. 2005; 78(2): 125–34. Epub 20041128. doi: 10.1016/j.drugalcdep.2004.10.004. PubMed PMID: 15845315.15845315
56 Barry D, Sullivan B, Petry NM. Comparable efficacy of contingency management for cocaine dependence among African American, Hispanic, and White methadone maintenance clients. Psychol Addict Behav. 2009; 23(1): 168–74. doi: 10.1037/a0014575. PubMed PMID: 19290703; PubMed Central PMCID: PMC2796365.19290703
57 DeFulio A, Stitzer M, Roll J, Petry N, Nuzzo P, Schwartz RP, Criminal justice referral and incentives in outpatient substance abuse treatment. J Subst Abuse Treat. 2013; 45(1): 70–5. Epub 20130219. doi: 10.1016/j.jsat.2012.12.012. PubMed PMID: 23433822; PubMed Central PMCID: PMC3645315.23433822
58 Mancino MJ, McGaugh J, Feldman Z, Poling J, Oliveto A. Effect of PTSD diagnosis and contingency management procedures on cocaine use in dually cocaine- and opioid-dependent individuals maintained on LAAM: A retrospective analysis. American Journal on Addictions. 2010; 19(2): 169–77. doi: 10.1111/j.1521-0391.2009.00025.x. PubMed PMID: 20163389.20163389
59 McDonell MG, Hirchak KA, Herron J, Lyons AJ, Alcover KC, Shaw J, Effect of incentives for alcohol abstinence in partnership with 3 American Indian and Alaska Native Communities: A randomized clinical trial. JAMA Psychiatry. 2021; 78(6): 599–606. doi: 10.1001/jamapsychiatry.2020.4768. PubMed PMID: 33656561; PubMed Central PMCID: PMC7931140.33656561
60 McDonell MG, Skalisky J, Burduli E, Foote A Sr., Granbois A, Smoker K, The rewarding recovery study: A randomized controlled trial of incentives for alcohol and drug abstinence with a rural American Indian community. Addiction. 2021; 116(6): 1569–79. Epub 20210114. doi: 10.1111/add.15349. PubMed PMID: 33220122; PubMed Central PMCID: PMC8131263.33220122
61 McPherson SM, Burduli E, Smith CL, Herron J, Oluwoye O, Hirchak K, A review of contingency management for the treatment of substance-use disorders: Adaptation for underserved populations, use of experimental technologies, and personalized optimization strategies. Substance Abuse & Rehabilitation. 2018; 9: 43–57. doi: 10.2147/SAR.S138439. PubMed PMID: 30147392.30147392
62 Murphy SM, McDonell MG, McPherson S, Srebnik D, Angelo F, Roll JM, An economic evaluation of a contingency-management intervention for stimulant use among community mental health patients with serious mental illness. Drug & Alcohol Dependence. 2015; 153: 293–9. Epub 2015/05/14. doi: 10.1016/j.drugalcdep.2015.05.004. PubMed PMID: 26026494.26026494
63 Rash CJ, Olmstead TA, Petry NM. Income does not affect response to contingency management treatments among community substance abuse treatment-seekers. Drug Alcohol Depend. 2009; 104(3): 249–53. Epub 20090708. doi: 10.1016/j.drugalcdep.2009.05.018. PubMed PMID: 19586727; PubMed Central PMCID: PMC2746932.19586727
64 Tracy K, Babuscio T, Nich C, Kiluk B, Carroll KM, Petry NM, Contingency management to reduce substance use in individuals who are homeless with co-occurring psychiatric disorders. Am J Drug Alcohol Abuse. 2007; 33(2): 253–8. doi: 10.1080/00952990601174931. PubMed PMID: 17497548; PubMed Central PMCID: PMC3390023.17497548
65 Patton SR. Adherence to glycemic monitoring in diabetes. J Diabetes Sci Technol. 2015; 9(3): 668–75. Epub 20150114. doi: 10.1177/1932296814567709. PubMed PMID: 25591853; PubMed Central PMCID: PMC4604539.25591853
66 Sanchez AL, Cornacchio D, Poznanski B, Golik AM, Chou T, Comer JS. The effectiveness of school-based mental health services for elementary-aged children: A meta-analysis. J Am Acad Child Adolesc Psychiatry. 2018; 57(3): 153–65. Epub 20171224. doi: 10.1016/j.jaac.2017.11.022. PubMed PMID: 29496124.29496124
67 Glass JE, Nunes EV, Bradley KA. Health Affairs Blog [Internet] 2020. [cited 2023]. Available from: https://www.healthaffairs.org/content/forefront/contingency-management-highly-effective-treatment-substance-use-disorders-and-legal.
68 Compton WM, Wargo EM, Volkow ND. Neuropsychiatric model of addiction simplified. Psychiatric Clinics of North America. 2022; 45(3): 321–34. doi: 10.1016/j.psc.2022.05.001.36055726
69 Volkow ND, Michaelides M, Baler R. The neuroscience of drug reward and addiction. Physiol Rev. 2019; 99(4): 2115–40. doi: 10.1152/physrev.00014.2018. PubMed PMID: 31507244; PubMed Central PMCID: PMC6890985.31507244
70 Ceceli AO, Bradberry CW, Goldstein RZ. The neurobiology of drug addiction: Cross-species insights into the dysfunction and recovery of the prefrontal cortex. Neuropsychopharmacology. 2022; 47(1): 276–91. Epub 20210818. doi: 10.1038/s41386-021-01153-9. PubMed PMID: 34408275; PubMed Central PMCID: PMC8617203.34408275
71 Caprioli D, Venniro M, Zeric T, Li X, Adhikary S, Madangopal R, Effect of the Novel Positive Allosteric Modulator of Metabotropic Glutamate Receptor 2 AZD8529 on incubation of Methamphetamine Craving after prolonged voluntary abstinence in a rat model. Biological Psychiatry. 2015; 78(7): 463–73. doi: 10.1016/j.biopsych.2015.02.018.25861699
72 Venniro M, Zhang M, Caprioli D, Hoots JK, Golden SA, Heins C, Volitional social interaction prevents drug addiction in rat models. Nature Neuroscience. 2018; 21(11): 1520–9. doi: 10.1038/s41593-018-0246-6.30323276
73 Maddern XJ, Walker LC, Campbell EJ, Arunogiri S, Haber PS, Morley K, Can we enhance the clinical efficacy of cognitive and psychological approaches to treat substance use disorders through understanding their neurobiological mechanisms? Neurosci Biobehav Rev. 2022; 142: 104899. Epub 20220929. doi: 10.1016/j.neubiorev.2022.104899. PubMed PMID: 36183863.36183863
74 Regier PS, Redish AD. Contingency management and deliberative decision-making processes. Front Psychiatry. 2015; 6: 76. Epub 20150601. doi: 10.3389/fpsyt.2015.00076. PubMed PMID: 26082725; PubMed Central PMCID: PMC4450586.26082725
75 Volkow ND, Wang G- J, Smith L, Fowler JS, Telang F, Logan J, Recovery of dopamine transporters with methamphetamine detoxification is not linked to changes in dopamine release. NeuroImage. 2015; 121: 20–8. doi: 10.1016/j.neuroimage.2015.07.035.26208874
76 Parvaz MA, Rabin RA, Adams F, Goldstein RZ. Structural and functional brain recovery in individuals with substance use disorders during abstinence: A review of longitudinal neuroimaging studies. Drug Alcohol Depend. 2022; 232: 109319. Epub 20220119. doi: 10.1016/j.drugalcdep.2022.109319. PubMed PMID: 35077955; PubMed Central PMCID: PMC8885813.35077955
77 Martinez D, Carpenter KM, Liu F, Slifstein M, Broft A, Friedman AC, Imaging dopamine transmission in cocaine dependence: Link between neurochemistry and response to treatment. Am J Psychiatry. 2011; 168(6): 634–41. Epub 20110315. doi: 10.1176/appi.ajp.2010.10050748. PubMed PMID: 21406463; PubMed Central PMCID: PMC3235735.21406463
78 Morie KP, DeVito EE, Potenza MN, Worhunsky PD. Longitudinal changes in network engagement during cognitive control in cocaine use disorder. Drug Alcohol Depend. 2021; 229(Pt A): 109151. Epub 20211030. doi: 10.1016/j.drugalcdep.2021.109151. PubMed PMID: 34753083; PubMed Central PMCID: PMC8671376.34753083
79 Farrell M, Martin NK, Stockings E, Bórquez A, Cepeda JA, Degenhardt L, Responding to global stimulant use: Challenges and opportunities. Lancet. 2019; 394(10209): 1652–67. Epub 20191023. doi: 10.1016/s0140-6736(19)32230-5. PubMed PMID: 31668409; PubMed Central PMCID: PMC6924572.31668409
80 The ASAM National Practice Guideline for the Treatment of Opioid Use Disorder: 2020 Focused Update. J Addict Med. 2020; 14(2S Suppl 1): 1–91. doi: 10.1097/adm.0000000000000633. PubMed PMID: 32511106.32511106
81 Bolívar HA, Klemperer EM, Coleman SR M, DeSarno M, Skelly JM, Higgins ST. Contingency management for patients receiving medication for opioid use disorder: A systematic review and meta-analysis. JAMA Psychiatry. 2021; 78(10): 1092–102. doi: 10.1001/jamapsychiatry.2021.1969. PubMed PMID: 34347030; PubMed Central PMCID: PMC8340014.34347030
82 Connor JP, Stjepanović D, Le Foll B, Hoch E, Budney AJ, Hall WD. Cannabis use and cannabis use disorder. Nat Rev Dis Primers. 2021; 7(1): 16. Epub 20210225. doi: 10.1038/s41572-021-00247-4. PubMed PMID: 33627670; PubMed Central PMCID: PMC8655458.33627670
83 Dougherty DM, Karns TE, Mullen J, Liang Y, Lake SL, Roache JD, Transdermal alcohol concentration data collected during a contingency management program to reduce at-risk drinking. Drug & Alcohol Dependence. 2015; 148: 77–84. Epub 2014/12/31. doi: 10.1016/j.drugalcdep.2014.12.021. PubMed PMID: 25582388.25582388
84 Alessi SM, Petry NM. A randomized study of cellphone technology to reinforce alcohol abstinence in the natural environment. Addiction. 2013; 108(5): 900–9. Epub 20130130. doi: 10.1111/add.12093. PubMed PMID: 23279560; PubMed Central PMCID: PMC3662495.23279560
85 Getty CA, Morande A, Lynskey M, Weaver T, Metrebian N. Mobile telephone-delivered contingency management interventions promoting behaviour change in individuals with substance use disorders: A meta-analysis. Addiction. 2019; 114(11): 1915–25. Epub 20190727. doi: 10.1111/add.14725. PubMed PMID: 31265747; PubMed Central PMCID: PMC6852192.31265747
86 McDonell MG, Leickly E, McPherson S, Skalisky J, Srebnik D, Angelo F, A randomized controlled trial of ethyl glucuronide-based contingency management for outpatients with cooccurring alcohol use disorders and serious mental illness. American Journal of Psychiatry. 2017; 174(4): 370–7.28135843
87 van der Windt M, van Zundert SK M, Schoenmakers S, Jansen PW, van Rossem L, Steegers-Theunissen RP M. Effective psychological therapies to improve lifestyle behaviors in (pre)pregnant women: A systematic review. Prev Med Rep. 2021; 24: 101631. Epub 20211109. doi: 10.1016/j.pmedr.2021.101631. PubMed PMID: 34976684; PubMed Central PMCID: PMC8683997.34976684
88 Lai H, Bluemke DA, Fishman EK, Gerstenblith G, Celentano DD, Treisman G, High-risk coronary plaque regression in cash-based contingency management intervention among cocaine users with HIV-associated Subclinical Coronary Atherosclerosis. J Addict Med. 2023; 17(2): 147–54. Epub 20220824. doi: 10.1097/adm.0000000000001057. PubMed PMID: 36001073.36001073
89 Carrico AW, Neilands TB, Dilworth SE, Evans JL, Gόmez W, Jain JP, Randomized controlled trial of a positive affect intervention to reduce HIV viral load among sexual minority men who use methamphetamine. J Int AIDS Soc. 2019; 22(12): e25436. doi: 10.1002/jia2.25436. PubMed PMID: 31860172; PubMed Central PMCID: PMC6924317.31860172
90 Scavella E. Testimony to the Senate Committee on Veterans' Affairs; 2023. Available from: https://www.veterans.senate.gov/services/files/CFEB8D42-EA25-4FEA-B3BE-B79A39919BB8.
91 Festinger DS, Dugosh KL, Kirby KC, Seymour BL. Contingency management for cocaine treatment: Cash vs. vouchers. J Subst Abuse Treat. 2014; 47(2): 168–74. Epub 20140306. doi: 10.1016/j.jsat.2014.03.001. PubMed PMID: 24746956; PubMed Central PMCID: PMC4504189.24746956
92 Higgins ST, Badger GJ, Budney AJ. Initial abstinence and success in achieving longer term cocaine abstinence. Exp Clin Psychopharmacol. 2000; 8(3): 377–86. doi: 10.1037//1064-1297.8.3.377. PubMed PMID: 10975629.10975629
93 Petry NM, Martin B, Simcic F Jr. Prize reinforcement contingency management for cocaine dependence: Integration with group therapy in a methadone clinic. J Consult Clin Psychol. 2005; 73(2): 354–9. doi: 10.1037/0022-006x.73.2.354. PubMed PMID: 15796645.15796645
94 Petry NM, Peirce JM, Stitzer ML, Blaine J, Roll JM, Cohen A, Effect of prize-based incentives on outcomes in stimulant abusers in outpatient psychosocial treatment programs: A national drug abuse treatment clinical trials network study. Arch Gen Psychiatry. 2005; 62(10): 1148–56. doi: 10.1001/archpsyc.62.10.1148. PubMed PMID: 16203960.16203960
95 Petry NM, Alessi SM, Hanson T. Contingency management improves abstinence and quality of life in cocaine abusers. J Consult Clin Psychol. 2007; 75(2): 307–15. doi: 10.1037/0022-006x.75.2.307. PubMed PMID: 17469888.17469888
96 Promberger M, Marteau TM. When do financial incentives reduce intrinsic motivation? Comparing behaviors studied in psychological and economic literatures. Health Psychology. 2013; 32(9): 950–7. doi: 10.1037/a0032727. PubMed PMID: 24001245.24001245
97 DeFulio A. Dissemination of contingency management for the treatment of opioid use disorder. Perspectives on Behavior Science. 2023; 46(1): 35–49. doi: 10.1007/s40614-022-00328-z.37006603
98 Rawson RA, Erath TG, Clark HW. The fourth wave of the overdose crisis: Examining the prominent role of psychomotor stimulants with and without fentanyl. Preventive Medicine. 2023: 107625. doi: 10.1016/j.ypmed.2023.107625.37468073
99 Kreidler M. California lawmakers push feds to allow a therapy that pays meth users to abstain. KFF Health News [Internet]. 2021 [cited 2023 July 24]. Available from: https://kffhealthnews.org/news/article/california-lawmakers-push-feds-to-allow-a-therapy-that-pays-meth-users-to-abstain/.
100 Proctor SL. Rewarding recovery: The time is now for contingency management for opioid use disorder. Ann Med. 2022; 54(1): 1178–87. doi: 10.1080/07853890.2022.2068805. PubMed PMID: 35471190; PubMed Central PMCID: PMC9045772.35471190
101 HHS Office of Inspector General (OIG). Medicare and State Health Care Programs: Fraud and Abuse; Revisions to Safe Harbors Under the Anti-Kickback Statute, and Civil Monetary Penalty Rules Regarding Beneficiary Inducements. Washington, DC: Federal Register; 2020. Available from: https://www.govinfo.gov/content/pkg/FR-2020-12-02/pdf/2020-26072.pdf.
102 Rash CJ, Stitzer M, Weinstock J. Contingency management: New directions and remaining challenges for an evidence-based intervention. J Subst Abuse Treat. 2017; 72: 10–8. Epub 20160928. doi: 10.1016/j.jsat.2016.09.008. PubMed PMID: 27746057; PubMed Central PMCID: PMC5154900.27746057
103 Roll JM, Madden GJ, Rawson R, Petry NM. Facilitating the adoption of contingency management for the treatment of substance use disorders. Behav Anal Pract. 2009; 2(1): 4–13. doi: 10.1007/bf03391732. PubMed PMID: 22477692; PubMed Central PMCID: PMC2854061.22477692
104 Petry NM, Barry D, Alessi SM, Rounsaville BJ, Carroll KM. A randomized trial adapting contingency management targets based on initial abstinence status of cocaine-dependent patients. J Consult Clin Psychol. 2012; 80(2): 276–85. Epub 20120109. doi: 10.1037/a0026883. PubMed PMID: 22229758; PubMed Central PMCID: PMC3668312.22229758
105 Stitzer ML, Gukasyan N, Matheson T, Sorensen JL, Feaster DJ, Duan R, Enhancing patient navigation with contingent financial incentives for substance use abatement in persons with HIV and substance use. Psychology of Addictive Behaviors. 2020; 34(1): 23.31436447
106 Willenbring ML, Hagedorn HJ, Postier AC, Kenny M. Variations in evidence-based clinical practices in nine United States Veterans Administration opioid agonist therapy clinics. Drug Alcohol Depend. 2004; 75(1): 97–106. doi: 10.1016/j.drugalcdep.2004.01.009. PubMed PMID: 15225893.15225893
107 Ritter A, Cameron J. Australian clinician attitudes towards contingency management: Comparing down under with America. Drug Alcohol Depend. 2007; 87(2–3): 312–5. Epub 20060912. doi: 10.1016/j.drugalcdep.2006.08.011. PubMed PMID: 16971057.16971057
108 Bride BE, Abraham AJ, Roman PM. Organizational factors associated with the use of contingency management in publicly funded substance abuse treatment centers. J Subst Abuse Treat. 2011; 40(1): 87–94. Epub 20100917. doi: 10.1016/j.jsat.2010.08.001. PubMed PMID: 20850259; PubMed Central PMCID: PMC2997916.20850259
109 Carroll C, Patterson M, Wood S, Booth A, Rick J, Balain S. A conceptual framework for implementation fidelity. Implement Sci. 2007; 2: 40. Epub 20071130. doi: 10.1186/1748-5908-2-40. PubMed PMID: 18053122; PubMed Central PMCID: PMC2213686.18053122
110 Damschroder LJ, Aron DC, Keith RE, Kirsh SR, Alexander JA, Lowery JC. Fostering implementation of health services research findings into practice: A consolidated framework for advancing implementation science. Implement Sci. 2009; 4: 50. Epub 20090807. doi: 10.1186/1748-5908-4-50. PubMed PMID: 19664226; PubMed Central PMCID: PMC2736161.19664226
111 Ducharme LJ, Knudsen HK, Roman PM, Johnson JA. Innovation adoption in substance abuse treatment: Exposure, trialability, and the Clinical Trials Network. J Subst Abuse Treat. 2007; 32(4): 321–9. Epub 20070222. doi: 10.1016/j.jsat.2006.05.021. PubMed PMID: 17481455; PubMed Central PMCID: PMC2365704.17481455
112 Hartzler B, Lash SJ, Roll JM. Contingency management in substance abuse treatment: A structured review of the evidence for its transportability. Drug Alcohol Depend. 2012; 122(1–2): 1–10. Epub 20111209. doi: 10.1016/j.drugalcdep.2011.11.011. PubMed PMID: 22153943; PubMed Central PMCID: PMC3307900.22153943
113 Petry NM. Contingency management treatments: Controversies and challenges. Addiction. 2010; 105(9): 1507–9. doi: 10.1111/j.1360-0443.2009.02879.x. PubMed PMID: 20707772; PubMed Central PMCID: PMC3049167.20707772
114 Henggeler SW, Chapman JE, Rowland MD, Halliday-Boykins CA, Randall J, Shackelford J, Statewide adoption and initial implementation of contingency management for substance-abusing adolescents. J Consult Clin Psychol. 2008; 76(4): 556–67. doi: 10.1037/0022-006x.76.4.556. PubMed PMID: 18665685; PubMed Central PMCID: PMC2603081.18665685
115 Petry NM, Alessi SM, Ledgerwood DM, Sierra S. Psychometric properties of the contingency management competence scale. Drug Alcohol Depend. 2010; 109(1–3): 167–74. Epub 20100211. doi: 10.1016/j.drugalcdep.2009.12.027. PubMed PMID: 20149950; PubMed Central PMCID: PMC2875270.20149950
116 Starcevic V, Khazaal Y. Relationships between behavioural addictions and psychiatric disorders: What is known and what is yet to be learned? Front Psychiatry. 2017; 8: 53. Epub 20170407. doi: 10.3389/fpsyt.2017.00053. PubMed PMID: 28439243; PubMed Central PMCID: PMC5383701.28439243
117 Peirce JM, Petry NM, Stitzer ML, Blaine J, Kellogg S, Satterfield F, Effects of lower-cost incentives on stimulant abstinence in methadone maintenance treatment: A National Drug Abuse Treatment Clinical Trials Network study. Arch Gen Psychiatry. 2006; 63(2): 201–8. doi: 10.1001/archpsyc.63.2.201. PubMed PMID: 16461864.16461864
118 Higgins ST, Silverman K, Heil SH, editors. Contingency Management in Substance Abuse Treatment. New York, NY: Guilford Press; 2008.
119 Petry NM, Tedford J, Austin M, Nich C, Carroll KM, Rounsaville BJ. Prize reinforcement contingency management for treating cocaine users: How low can we go, and with whom? Addiction. 2004; 99(3): 349–60. doi: 10.1111/j.1360-0443.2003.00642.x. PubMed PMID: 14982548; PubMed Central PMCID: PMC3709247.14982548
120 Kellogg SH, Kreek MJ. Gradualism, identity, reinforcements, and change. International Journal of Drug Policy. 2005; 16(6): 369–75.
121 Petry N, Maxine L, Stitzer. Contingency Management: Using Motivational Incentives to Improve Drug Abuse Treatment. 2002.
122 Esang M, Ahmed S. A closer look at substance use and suicide. American Journal of Psychiatry Residents' Journal. 2018; 13(6): 6–8. doi: 10.1176/appi.ajp-rj.2018.130603.
123 Ford M, Håkansson A. Problem gambling, associations with comorbid health conditions, substance use, and behavioural addictions: Opportunities for pathways to treatment. PLoS One. 2020; 15(1): e0227644. Epub 20200110. doi: 10.1371/journal.pone.0227644. PubMed PMID: 31923269; PubMed Central PMCID: PMC6953879.31923269
124 Maccallum F, Blaszczynski A. Pathological gambling and comorbid substance use. Aust N Z J Psychiatry. 2002; 36(3): 411–5. doi: 10.1046/j.1440-1614.2001.01005.x. PubMed PMID: 12060192.12060192
125 Rash CJ, Weinstock J, Van Patten R. A review of gambling disorder and substance use disorders. Subst Abuse Rehabil. 2016; 7: 3–13. Epub 20160317. doi: 10.2147/sar.S83460. PubMed PMID: 27051333; PubMed Central PMCID: PMC4803266.27051333
126 Petry NM, Stinson FS, Grant BF. Comorbidity of DSM-IV pathological gambling and other psychiatric disorders: Results from the National Epidemiologic Survey on Alcohol and Related Conditions. J Clin Psychiatry. 2005; 66(5): 564–74. doi: 10.4088/jcp.v66n0504. PubMed PMID: 15889941.15889941
127 Rodriguez-Monguio R, Errea M, Volberg R. Comorbid pathological gambling, mental health, and substance use disorders: Health-care services provision by clinician specialty. J Behav Addict. 2017; 6(3): 406–15. Epub 20170831. doi: 10.1556/2006.6.2017.054. PubMed PMID: 28856904; PubMed Central PMCID: PMC5700728.28856904
128 Najavits L, Lung J, Froias A, Paull N, Bailey G. A study of multiple behavioral addictions in a substance abuse sample. Subst Use Misuse. 2014; 49(4): 479–84. Epub 20131204. doi: 10.3109/10826084.2013.858168. PubMed PMID: 24304172.24304172
129 Reid RC, Meyer MD. Substance use disorders in hypersexual adults. Current Addiction Reports. 2016; 3(4): 400–5. doi: 10.1007/s40429-016-0124-9.
130 Frangos CC, Frangos CC, Sotiropoulos I. Problematic Internet use among Greek university students: An ordinal logistic regression with risk factors of negative psychological beliefs, pornographic sites, and online games. Cyberpsychol Behav Soc Netw. 2011; 14(1–2): 51–8. Epub 20100526. doi: 10.1089/cyber.2009.0306. PubMed PMID: 21329443.21329443
131 DeFulio A, Rzeszutek MJ, Furgeson J, Ryan S, Rezania S. A smartphone-smartcard platform for contingency management in an inner-city substance use disorder outpatient program. J Subst Abuse Treat. 2021; 120: 108188. Epub 20201102. doi: 10.1016/j.jsat.2020.108188. PubMed PMID: 33298295.33298295
132 Dallery J, Defulio A, RaiffBR. Digital contingency management in the treatment of substance use disorders. Policy Insights from the Behavioral & Brain Sciences. 2023; 10(1): 51–8. doi: 10.1177/23727322221144648.
133 HHS Office of Inspector General (OIG). Advisory Opinion No. 22–04; 2022. Washington, DC. Available from: https://oig.hhs.gov/documents/advisory-opinions/1024/AO-22-04.pdf.
134 Pfund RA, Cook JE, McAfee NW, Huskinson SL, Parker JD. Challenges to conducting contingency management treatment for substance use disorders: Practice recommendations for clinicians. Prof Psychol Res Pr. 2021; 52(2): 137–45. Epub 20210222. doi: 10.1037/pro0000356. PubMed PMID: 34421192; PubMed Central PMCID: PMC8372300.34421192
135 Griffith JD, Rowan-Szal GA, Roark RR, Simpson DD. Contingency management in outpatient methadone treatment: A meta-analysis. Drug Alcohol Depend. 2000; 58(1–2): 55–66. doi: 10.1016/s0376-8716(99)00068-x. PubMed PMID: 10669055.10669055
136 Trotman AJ, Taxman FS. Implementation of a contingency management-based intervention in a community supervision setting: Clinical issues and recommendations. J Offender Rehabil. 2011; 50(5): 235–51. doi: 10.1080/10509674.2011.585924. PubMed PMID: 22235164; PubMed Central PMCID: PMC3253349.22235164
137 Volpp KG, Gurmankin Levy A, Asch DA, Berlin JA, Murphy JJ, Gomez A, A randomized controlled trial of financial incentives for smoking cessation. Cancer Epidemiol Biomarkers Prev. 2006; 15(1): 12–8. doi: 10.1158/1055-9965.Epi-05-0314. PubMed PMID: 16434580.16434580
138 Herrmann ES, Matusiewicz AK, Stitzer ML, Higgins ST, Sigmon SC, Heil SH. Contingency management interventions for HIV, Tuberculosis, and Hepatitis control among individuals with substance use disorders: A systematized review. J Subst Abuse Treat. 2017; 72: 117–25. Epub 20160624. doi: 10.1016/j.jsat.2016.06.009. PubMed PMID: 27394070; PubMed Central PMCID: PMC5386179.27394070
139 Khazanov GK, Morris PE, Beed A, Jager-Hyman S, Myhre K, McKay JR, Do financial incentives increase mental health treatment engagement? A meta-analysis. J Consult Clin Psychol. 2022; 90(6): 528–44. doi: 10.1037/ccp0000737. PubMed PMID: 35771513.35771513
140 DePhilippis D. Contingency Management for the Treatment of Stimulant Use Disorder: Indiana University School of Medicine -- Project ECHO; 2021. Available from: https://oudecho.iu.edu/resources/downloads/Contingency%20Management.pdf.
141 Taylor JL, Samet JH. Opioid use disorder. Annals of Internal Medicine. 2022; 175(1): ITC1–ITC16. doi: 10.7326/aitc202201180%m35007147.35007147
142 White JM, Irvine RJ. Mechanisms of fatal opioid overdose. Addiction. 1999; 94(7): 961–72. PubMed PMID: 10707430.10707430
143 Volkow ND. The epidemic of fentanyl misuse and overdoses: Challenges and strategies. World Psychiatry. 2021; 20(2): 195–6. doi: 10.1002/wps.20846. PubMed PMID: 34002497; PubMed Central PMCID: PMC8129846.34002497
144 Cousins G, Boland F, Courtney B, Barry J, Lyons S, Fahey T. Risk of mortality on and off methadone substitution treatment in primary care: A national cohort study. Addiction. 2016; 111(1): 73–82. Epub 20150928. doi: 10.1111/add.13087. PubMed PMID: 26234389.26234389
145 Kale N. Urine drug tests: Ordering and interpretation. American Family Physician. 2019; 99(1): 33–9.30600984
146 Li Z, Wang P. Point-of-care drug of abuse testing in the opioid epidemic. Archives of Pathology & Laboratory Medicine. 2020; 144(11): 1325–34. doi: 10.5858/arpa.2020-0055-RA.32579399
147 McMillin GA, Johnson-Davis KL, Kelly BN, Scott B, Yang YK. Impact of the opioid epidemic on drug testing. Therapeutic Drug Monitoring. 2021; 43(1): 14–24. doi: 10.1097/ftd.0000000000000841. PubMed PMID: 00007691-202102000-00003.33230043
148 American Society of Addiction Medicine. Appropriate Use of Drug Testing in Clinical Addiction Medicine. Rockville, MD2017. Available from: https://sitefinitystorage.blob.core.windows.net/sitefinity-production-blobs/docs/default-source/guidelines/the-asam-appropriate-use-of-drug-testing-in-clinical-addiction-medicine-full-document.pdf?sfvrsn=700a7bc2_0.
149 Budney AJ, Stanger C, Tilford JM, Scherer EB, Brown PC, Li Z, Computer-assisted behavioral therapy and contingency management for cannabis use disorder. Psychol Addict Behav. 2015; 29(3): 501–11. Epub 20150504. doi: 10.1037/adb0000078. PubMed PMID: 25938629; PubMed Central PMCID: PMC4586287.25938629
150 Litt MD, Kadden RM, Petry NM. Behavioral treatment for marijuana dependence: Randomized trial of contingency management and self-efficacy enhancement. Addict Behav. 2013; 38(3): 1764–75. Epub 20120831. doi: 10.1016/j.addbeh.2012.08.011. PubMed PMID: 23254227; PubMed Central PMCID: PMC3558664.23254227
151 Amlung M, Vedelago L, Acker J, Balodis I, MacKillop J. Steep delay discounting and addictive behavior: A meta-analysis of continuous associations. Addiction. 2017; 112(1): 51–62. Epub 20160901. doi: 10.1111/add.13535. PubMed PMID: 27450931; PubMed Central PMCID: PMC5148639.27450931
152 Davis-Martin RE, Alessi SM, Boudreaux ED. Alcohol use disorder in the age of technology: A review of wearable biosensors in alcohol use disorder treatment. Frontiers in Psychiatry. 2021; 12: 246.
153 Orr MF, Lederhos Smith C, Finlay M, Martin SC, Brooks O, Oluwoye OA, Pilot investigation: Randomized-controlled analog trial for alcohol and tobacco smoking co-addiction using contingency management. Behav Pharmacol. 2018; 29(5): 462–8. doi: 10.1097/FBP.0000000000000379. PubMed PMID: 29561290; PubMed Central PMCID: PMC6035091.29561290
154 Schepis TS, Duhig AM, Liss T, McFetridge A, Wu R, Cavallo DA, Contingency management for smoking cessation: Enhancing feasibility through use of immunoassay test strips measuring cotinine. Nicotine & Tobacco Research. 2008; 10(9): 1495–501. doi: 10.1080/14622200802323209. PubMed PMID: 19023841.19023841
155 Verification SSoB. Biochemical verification of tobacco use and cessation. Nicotine & Tobacco Research. 2002; 4(2): 149–59.12028847
156 DeFulio A, Everly JJ, Leoutsakos JM, Umbricht A, Fingerhood M, Bigelow GE, Employment-based reinforcement of adherence to an FDA approved extended release formulation of naltrexone in opioid-dependent adults: A randomized controlled trial. Drug Alcohol Depend. 2012; 120(1–3): 48–54. Epub 20110722. doi: 10.1016/j.drugalcdep.2011.06.023. PubMed PMID: 21782353; PubMed Central PMCID: PMC3245785.21782353
157 Everly JJ, DeFulio A, Koffarnus MN, Leoutsakos JM, Donlin WD, Aklin WM, Employment-based reinforcement of adherence to depot naltrexone in unemployed opioid-dependent adults: A randomized controlled trial. Addiction. 2011; 106(7): 1309–18. Epub 20110503. doi: 10.1111/j.1360-0443.2011.03400.x. PubMed PMID: 21320227; PubMed Central PMCID: PMC3107896.21320227
158 Dunn KE, Defulio A, Everly JJ, Donlin WD, Aklin WM, Nuzzo PA, Employment-based reinforcement of adherence to oral naltrexone treatment in unemployed injection drug users. Exp Clin Psychopharmacol. 2013; 21(1): 74–83. Epub 20121203. doi: 10.1037/a0030743. PubMed PMID: 23205722; PubMed Central PMCID: PMC3641088.23205722
159 Carroll KM, Ball SA, Nich C, O'Connor PG, Eagan DA, Frankforter TL, Targeting behavioral therapies to enhance naltrexone treatment of opioid dependence: Efficacy of contingency management and significant other involvement. Arch Gen Psychiatry. 2001; 58(8): 755–61. doi: 10.1001/archpsyc.58.8.755. PubMed PMID: 11483141; PubMed Central PMCID: PMC3651594.11483141
160 Carroll KM, Sinha R, Nich C, Babuscio T, Rounsaville BJ. Contingency management to enhance naltrexone treatment of opioid dependence: A randomized clinical trial of reinforcement magnitude. Exp Clin Psychopharmacol. 2002; 10(1): 54–63. doi: 10.1037//1064-1297.10.1.54. PubMed PMID: 11866252.11866252
161 Preston KL, Silverman K, Umbricht A, DeJesus A, Montoya ID, Schuster CR. Improvement in naltrexone treatment compliance with contingency management. Drug Alcohol Depend. 1999; 54(2): 127–35. doi: 10.1016/s0376-8716(98)00152-5. PubMed PMID: 10217552.10217552
162 Kidorf M, Brooner RK, Leoutsakos JM, Peirce J. Treatment initiation strategies for syringe exchange referrals to methadone maintenance: A randomized clinical trial. Drug Alcohol Depend. 2018; 187: 343–50. Epub 20180416. doi: 10.1016/j.drugalcdep.2018.03.009. PubMed PMID: 29709732.29709732
163 Wenzel K, Selby V, Wildberger J, Lavorato L, Thomas J, Fishman M. Choice of extended release medication for OUD in young adults (buprenorphine or naltrexone): A pilot enhancement of the Youth Opioid Recovery Support (YORS) intervention. J Subst Abuse Treat. 2021; 125: 108306. Epub 20210126. doi: 10.1016/j.jsat.2021.108306. PubMed PMID: 34016297.34016297
164 Metrebian N, Carr E, Goldsmith K, Weaver T, Pilling S, Shearer J, Mobile telephone delivered contingency management for encouraging adherence to supervised methadone consumption: Feasibility study for an RCT of clinical and cost-effectiveness (TIES). Pilot Feasibility Stud. 2021; 7(1): 14. Epub 20210107. doi: 10.1186/s40814-020-00761-4. PubMed PMID: 33407950; PubMed Central PMCID: PMC7789356.33407950
165 DeFulio A, Brown HD, Davidson RM, Regnier SD, Kang N, Ehart M. Feasibility, acceptability, and preliminary efficacy of a smartphone-based contingency management intervention for Buprenorphine adherence. Behavior Analysis in Practice. 2023; 16(2): 450–8. doi: 10.1007/s40617-022-00730-8.37187840
166 Holtyn AF, Toegel F, Novak MD, Leoutsakos J- M, Fingerhood M, Silverman K. Remotely delivered incentives to promote buprenorphine treatment engagement in out-of-treatment adults with opioid use disorder. Drug & Alcohol Dependence. 2021; 225: 108786. doi: 10.1016/j.drugalcdep.2021.108786.34087746
167 Batastini AB, Paprzycki P, Jones AC T, MacLean N. Are videoconferenced mental and behavioral health services just as good as in-person? A meta-analysis of a fast-growing practice. Clinical Psychology Review. 2021; 83: 101944. doi: 10.1016/j.cpr.2020.101944.33227560
168 Furukawa S, Hagi K, Kurokawa S, Takamiya A, Fujikawa M, Kinoshita S, Telepsychiatry versus face-to-face treatment: A systematic review and meta-analysis of randomized controlled trials. Neuroscience Applied. 2022; 1: 100320. doi: 10.1016/j.nsa.2022.100320.
169 Snoswell CL, Chelberg G, De Guzman KR, Haydon HH, Thomas EE, Caffery LJ, The clinical effectiveness of telehealth: A systematic review of meta-analyses from 2010 to 2019. Journal of Telemedicine & Telecare. doi: 10.1177/1357633x211022907. PubMed PMID: 34184580.34184580
170 Wilson SM, Blalock DV, Young JR, Griffin SC, Hertzberg JS, Calhoun PS, Mobile health contingency management for smoking cessation among veterans experiencing homelessness: A comparative effectiveness trial. Preventive Medicine Reports. 2023; 35: 102311. doi: 10.1016/j.pmedr.2023.102311.37455761
171 Miguel AQ, Smith CL, Rodin NM, Johnson RK, McDonell MG, McPherson SM. Automated Reinforcement Management System: Feasibility study findings of an app-based contingency management treatment for alcohol use disorder. Drug & Alcohol Dependence Reports. 2023; 6: 100140. doi: 10.1016/j.dadr.2023.100140.36994367
172 Beckham JC, Adkisson KA, Hertzberg J, Kimbrel NA, Budney AJ, Stephens RS, Mobile contingency management as an adjunctive treatment for co-morbid cannabis use disorder and cigarette smoking. Addictive Behaviors. 2018; 79: 86–92. Epub 2017/12/06. doi: 10.1016/j.addbeh.2017.12.007. PubMed PMID: 29268146.29268146
173 Hammond AS, Sweeney MM, Chikosi TU, Stitzer ML. Digital delivery of a contingency management intervention for substance use disorder: A feasibility study with DynamiCare Health. Journal of Substance Abuse Treatment. 2021; 126: 108425. doi: 10.1016/j.jsat.2021.108425.34116816
174 Kong G, Goldberg AL, Dallery J, Krishnan-Sarin S. An open-label pilot study of an intervention using mobile phones to deliver contingency management of tobacco abstinence to high school students. Exp Clin Psychopharmacol. 2017; 25(5): 333–7. doi: 10.1037/pha0000151. PubMed PMID: 29048181; PubMed Central PMCID: PMC5687821.29048181
175 Stanger C, Budney AJ. Contingency management: Using incentives to improve outcomes for adolescent substance use disorders. Pediatric Clinics of North America. 2019; 66(6): 1183–92. doi: 10.1016/j.pcl.2019.08.007. PubMed PMID: 31679606.31679606
176 Adams ZW, Marriott BR, Hulvershorn LA, Hinckley J. Treatment of adolescent cannabis use disorders. Child & Adolescent Psychiatric Clinics of North America. 2023; 32(1): 141–55. doi: 10.1016/j.chc.2022.07.006.36410901
177 Petry NM, Alessi SM, Ledgerwood DM. A randomized trial of contingency management delivered by community therapists. J Consult Clin Psychol. 2012; 80(2): 286–98. Epub 20120116. doi: 10.1037/a0026826. PubMed PMID: 22250852; PubMed Central PMCID: PMC3725552.22250852
178 Petry NM, Alessi SM, Ledgerwood DM. Contingency management delivered by community therapists in outpatient settings. Drug Alcohol Depend. 2012; 122(1–2): 86–92. Epub 20111005. doi: 10.1016/j.drugalcdep.2011.09.015. PubMed PMID: 21981991; PubMed Central PMCID: PMC3290694.21981991
179 Helseth SA, Janssen T, Scott K, Squires DD, Becker SJ. Training community-based treatment providers to implement contingency management for opioid addiction: Time to and frequency of adoption. J Subst Abuse Treat. 2018; 95: 26–34. Epub 20180911. doi: 10.1016/j.jsat.2018.09.004. PubMed PMID: 30352667; PubMed Central PMCID: PMC6209121.30352667
180 Andrzejewski ME, Kirby KC, Morral AR, Iguchi MY. Technology transfer through performance management: The effects of graphical feedback and positive reinforcement on drug treatment counselors' behavior. Drug Alcohol Depend. 2001; 63(2): 179–86. doi: 10.1016/s0376-8716(00)00207-6. PubMed PMID: 11376922.11376922
181 Henggeler SW, Sheidow AJ, Cunningham PB, Donohue BC, Ford JD. Promoting the implementation of an evidence-based intervention for adolescent marijuana abuse in community settings: Testing the use of intensive quality assurance. J Clin Child Adolesc Psychol. 2008; 37(3): 682–9. doi: 10.1080/15374410802148087. PubMed PMID: 18645758.18645758