# EXECUTIVE SUMMARY

Stimulants represent a major and growing threat in the overdose crisis (1). Contingency management (CM) -- a psychosocial intervention that involves reinforcing abstinence from substances, as well as reinforcing other recovery-related behaviors -- is widely considered the most effective treatment for stimulant use disorder, and also has evidence as an effective treatment for alcohol, cannabis, and tobacco use disorders and as an effective adjunctive intervention to medications for opioid use disorder (MOUD) (2–4). While CM has been successfully implemented nationwide by the U.S. Department of Veterans Affairs (VA) and is permitted under several U.S. Department of Health and Human Services (HHS) grant programs and Medicaid demonstrations in California and Washington, it remains underutilized (5–8).

Several barriers limit the uptake of CM, including concerns about the potential application of certain federal fraud and abuse laws; limited funding and reimbursement opportunities; program restrictions on substance use disorders (SUDs) for which CM can be used; knowledge, attitudes and stigma related to CM; importance of strict fidelity to treatment protocols; limited access to training and mentoring; and workforce challenges (5, 8–13). Major barriers include concerns about the potential application of certain federal fraud and abuse laws, a $75 annual limit on the value of cumulative per client CM incentives in HHS grant programs, and misconceptions about CM.

There are many opportunities for entities overseeing CM implementation -- including, among others, regulators at the federal, state, Tribal, local, and territorial levels -- to overcome barriers to CM access, strengthen the quality of CM services, and promote program integrity. Key opportunities include ensuring the implementation of and fidelity to evidence-based treatment protocols, clarifying the application of certain federal fraud and abuse laws to CM incentives, disseminating best practices on CM implementation, raising incentive limits in federal grant programs to enable evidence-based CM delivery, and conducting evaluations of CM implemented in real-world settings (see Box 1 for recommendations) (5, 9, 14). Importantly, to promote program integrity and effectiveness, CM incentives should take the form of vouchers for items and services that support client well-being and recovery -- not cash payments.

Ultimately, there is immense need to expand the implementation of CM, as it has tremendous potential to address the nation’s high rate of overdose deaths and, in particular, the increasing rate of stimulant-involved overdose deaths.

Box 1 Summary of HHS Recommendations to Entities Overseeing Contingency Management Implementation for Improving Access and Quality and for Strengthening Program Integrity

Clinical Approach

1. Require that providers adhere to established, evidence-based, efficacious treatment protocols that incorporate objective verification of incentivized behaviors.
2. Establish voucher- and prize-based CM incentive magnitudes that are sufficiently high to reinforce recovery-related behaviors as demonstrated in the literature.
  a. If operational factors necessitate limits on cumulative per client incentive values, ensure that these limits allow for evidence-based incentive values and minimize the likelihood of premature treatment discontinuation.
3. Require the use of treatment protocols of at least 12 weeks duration when abstinence or treatment attendance are the incentivized behaviors.
4. Select incentives that are perceived as valuable to clients, including items, services, and vouchers or gift cards with purchase restrictions. Certain restrictions on incentives may be needed to effectively support recovery, mitigate risks of incentive diversion and misuse, and promote equity for clients. Due to this need, [underlined: cash and unrestricted cash equivalents should be disallowed as incentives].
  a. Recommended restrictions on incentives include:
    - Weapons;
    - Intoxicants (e.g., alcohol);
    - Over-the-counter preparations containing possible intoxicants (e.g., dextromethorphan);
    - Tobacco products;
    - Pornographic materials;
    - Gambling-related items (e.g., lottery tickets);
    - Enhanced or expedited access to SUD treatment or recovery support services; and
    - Parenting time.
5. Implement treatment protocols in which opportunities to receive incentives occur with sufficient frequency to effectively reinforce the desired behavior.
  a. Abstinence: twice or thrice weekly.
  b. Treatment session attendance: at least once weekly.
  c. Medication adherence (for medications administered monthly): once monthly.
6. Provide incentives immediately after the incentivized behavior is verified. For abstinence as an incentivized behavior, this requires the use of rapid point-of-care (POC) drug tests.
7. Consider prioritizing stimulant use disorder for CM over other SUDs, based on CM’s superior efficacy relative to other treatments for stimulant use disorder, its more robust evidence base for stimulant use disorder compared to other SUDs, the lack of Food and Drug Administration (FDA)-approved medications for stimulant use disorder, and the growing contribution of stimulants to overdose deaths. Targeting a broader set of SUDs with CM can, however, be a better strategy for certain communities depending on their needs.
8. Select incentivized behaviors that are appropriate for the substances being targeted, based on currently available drug testing technologies and medications.
  a. Abstinence: stimulant and cannabis use disorders.
    - Abstinence should be objectively verified using rapid POC tests waived under the Clinical Laboratory Improvement Amendments of 1998 (“CLIA”).
  b. Treatment session attendance: stimulant, opioid, cannabis, alcohol, and tobacco use disorders.
  c. Medication adherence (for long-acting medications): opioid use disorder (OUD).
9. Offer CM as part of a continuum of evidence-based treatment options and services for SUDs, as appropriate for the populations being served.
10. Consider using telehealth as a strategy to expand access to CM when SUD treatment session attendance is the incentivized behavior.

Provider and Organizational Standards

11. Implement the following training and coaching requirements for CM providers:
  a. CM providers must receive CM-specific training [underlined: before] offering CM, as well as ongoing coaching throughout their time delivering CM.
  b. CM coaches must receive CM-specific training prior to coaching.
  c. CM providers and coaches must receive regular continuing education on CM.
12. Permit any health care provider authorized to provide SUD treatment services to deliver CM. At this time, it is not recommended that peer support specialists be permitted to deliver CM.
13. Require that each office or facility providing CM designate one or more CM Champions, and that CM Champions receive training on evidence-based practices (EBPs) and periodic continuing education.
14. Consider requiring the development and approval of a readiness attestation before organizations may begin providing CM.
15. Require frequent monitoring of fidelity to EBPs using robust documentation systems and use the findings to implement program improvements and to target additional training and coaching investments.

Policy Opportunities

16. Align any limits on the value of incentives with the research evidence to maximize CM effectiveness.
17. Provide guidance or other clarifications that explain permissible CM activities under potentially applicable federal fraud and abuse laws to ensure maximum access to CM. In accordance with section 4127 of the Consolidated Appropriations Act, 2023, the HHS Office of Inspector General (OIG) and HHS are considering proposing a safe harbor for evidence-based CM incentives, which would include any parameters for such a safe harbor.
18. Publish and disseminate best practices for the implementation of CM in diverse settings.
19. Provide information that is tailored to different stakeholders to address misconceptions about CM.
20. Support research to further optimize CM delivery, including on areas such as repeat courses of treatment, optimal duration of treatment, and best practices for treating children and adolescents.
21. Conduct implementation and outcome evaluations of CM to ensure that practices that have enabled CM to be successful in research trials are optimally translated into real-world practice, as well as to identify new practices that promote effective CM implementation.
22. Implementation of CM that aligns with the existing evidence base should not be delayed while further research on optimizing CM delivery is conducted.