# ACRONYMS

BUP-ER: Extended-Release Injectable Buprenorphine
CBT: Cognitive Behavioral Therapy
CLIA: Clinical Laboratory Improvement Amendments of 1998
CM: Contingency Management
CMP: Civil Monetary Penalty
CMS: Centers for Medicare & Medicaid Services
CRA: Community Reinforcement Approach
EBP: Evidence-Based Practices
FDA: Food and Drug Administration
HHS: U.S. Department of Health and Human Services
MOUD: Medications for Opioid Use Disorder
NIDA: National Institute on Drug Abuse
OIG: HHS Office of Inspector General
OUD: Opioid Use Disorder
POC: Point-of-Care
SAMHSA: Substance Abuse and Mental Health Services Administration
SOR: State Opioid Response
SUD: Substance Use Disorder
VA: U.S. Department of Veterans Affairs
XR-naltrexone: Extended-Release Injectable Naltrexone