# CONCLUSION

CM is an established, evidence-based treatment for a variety of SUDs, and is the most effective currently available treatment for stimulant use disorder, which represents the fastest-growing category of substances involved in overdose deaths. CM remains underutilized, but as this report describes, there are numerous opportunities for health care providers, organizations delivering CM, entities that are overseeing the implementation of CM, as well as research, education, communications, funding, and regulatory entities to support broader access to high-quality CM through clinical, organizational, funding and policy strategies (see Box 1 for summary of recommendations). Accelerating our collective efforts to address the overdose crisis using all available effective tools is imperative to save lives and support recovery from SUDs -- CM can help advance our progress.