# BARRIERS

Despite its robust empirical support, CM has encountered numerous barriers to widespread implementation in clinical settings. Barriers include concerns about the potential application of certain federal fraud and abuse laws; limited funding and reimbursement opportunities (9, 97); program restrictions on SUDs for which CM can be used; knowledge, attitudes and stigma related to CM (8, 10–12, 98); importance of strict fidelity to treatment protocols (13); limited access to training and mentoring in CM (11); and workforce challenges. This section highlights the most significant barriers to implementing CM programs in clinical practice as identified by the existing research and stakeholder feedback.

## Concerns Regarding the Potential Application of Federal Fraud and Abuse Laws

Practitioners’ concerns regarding the application of certain federal fraud and abuse laws to CM incentives have chilled the wider implementation of CM (9, 67, 97, 99), and such concerns have been explicitly identified by HHS grantees as a barrier to delivering CM. Specifically, stakeholders have raised concerns that they could face criminal and monetary penalties under the federal anti-kickback statute (42 U.S.C. § 1320a-7b(b)), the civil monetary penalty provision prohibiting inducements to beneficiaries (“Beneficiary Inducements CMP”, 42 U.S.C. § 1320a-7a(a)(5)), or both in connection with providing CM incentives to a client who receives federally billable services from the same provider (5, 7, 100).

Practitioners’ concerns stem from the breadth of the prohibitions set forth in the federal anti-kickback statute and Beneficiary Inducements CMP and uncertainty regarding how those laws would apply to CM interventions involving federal health care program beneficiaries. The federal anti-kickback statute is a broad, intent-based criminal statute that, as a general matter, prohibits the exchange of anything of value for Medicare, Medicaid, and other federal health care program referrals (including self-referrals by federal health care program enrollees) or purchasing items or services paid for by Medicare, Medicaid, or other federal health care programs. The Beneficiary Inducements CMP provides for the imposition of civil monetary penalties against any person who offers or transfers anything of value to a Medicare or state health care program beneficiary that the person offering or transferring remuneration knows or should know is likely to influence the beneficiary’s selection of a particular provider, practitioner, or supplier of any item or service for which payment may be made, in whole or in part, by Medicare or a state health care program (including Medicaid). Whether or not CM incentives implicate -- and potentially violate -- these two laws would require an assessment of all of the facts and circumstances of the CM program, including the intent of the practitioner providing the CM incentive. Stakeholders have explained that the need to assess compliance with these laws on a case-by-case basis has contributed to uncertainty and confusion regarding what types of CM arrangements are legally permissible.

In addition, there is a widespread belief among stakeholders that guidance from OIG in connection with the federal anti-kickback statute and Beneficiary Inducements CMP limits CM incentives to a $75 annual value. While OIG has explained that this is a misunderstanding of its guidance and that “[t]here is no OIG-imposed $75 limitation on contingency management program incentives,” OIG also has stated that “[c]ontingency management incentive arrangements that do not comply with a safe harbor must be analyzed on a case-by-case basis for compliance with the Federal anti-kickback statute and Beneficiary Inducements CMP” (101). Again, stakeholders have raised concerns that the lack of legal certainty created by the necessity for case-by-case assessments has hindered broader use of CM incentives. As discussed further in the following section, HHS grants that support CM disallow the use of grant funds for CM incentives that exceed a $75 annual value threshold -- which studies show is too low to be effective -- to prevent cases of non-compliance with the Beneficiary Inducements CMP. Finally, stakeholders also have expressed confusion about whether advertising that they offer CM as a treatment would potentially result in liability under the federal anti-kickback statute or Beneficiary Inducements CMP.

In short, stakeholders have identified their concerns regarding the potential application of the federal anti-kickback statute and Beneficiary Inducements CMP, and the lack of certainty about whether CM incentives could be subject to criminal and monetary penalties, as a primary regulatory barrier to the increased implementation of CM. These concerns have similarly been raised by CM researchers and implementers in the published literature (9, 97).

## Insufficient Reimbursement and Funding Limitations

Insufficient reimbursement and funding limitations are among the most frequently cited barriers to the implementation of CM in clinical settings (5, 42, 102, 103). With few exceptions, CM is generally not reimbursed by public or private insurance programs. Providers therefore largely rely on grants to finance CM interventions, raising concerns about sustainability of CM programs beyond the life of the grant. In addition, a major limitation of federal grants has been their restriction on the level of funding that can be allocated toward CM incentives. HHS grants restrict the use of funds for CM incentives to a limit of $75 per client, per year through sub-regulatory grant requirements.^h^ This limit has been widely cited as non-evidence-based and an impediment to the delivery of effective CM protocols (9). As discussed in detail in a subsequent section of this report (“Opportunities to Improve Access and Quality and Strengthen Program Integrity”), the current scientific evidence clearly demonstrates that higher-value CM incentives are necessary to achieve positive behavior changes (3, 21, 104, 105). The average range of distributed CM incentives that have been found to be effective in the research literature over the years, during a typical 12-week treatment protocol, amounts to $300-$600 per client.^i^

Echoing this concern, among HHS grantees the $75 CM incentive value limit is the most frequently cited barrier to the wider implementation of CM and is noted to be among the most significant obstacles to the delivery of effective, evidence-based CM interventions. The SAMHSA SOR Program Office reports that, as of the publication of this report, at least 40 states^j^ across geographically diverse regions of the United States have requested an increase in the HHS grant limit for CM incentives, citing it as a barrier to the use of evidence-based treatment protocols. Several states have even communicated an unwillingness to implement CM using SOR funds unless the incentive limit is raised to an evidence-based amount. HHS grantees note that the current CM incentive limit has made it more challenging to engage and retain clients in their CM programs, and even makes providers reluctant to offer CM due to concerns that it precludes fidelity to effective protocols.

Financial limitations hinder other aspects of CM delivery as well, such as staff training and program administration (2, 103). As an example, HHS grantees noted that developing an infrastructure to safely store CM incentives prior to their disbursement to clients and to track disbursement is essential to safeguarding program integrity but often requires additional resources. Financial limitations are particularly pronounced in publicly funded treatment programs, which often struggle to obtain sufficient resources to implement and sustain evidence-based practices (40).

## Program Restrictions on SUDs for Which CM Can Be Used

As discussed above, CM is an effective treatment for stimulant, cannabis, alcohol, and tobacco use disorders, and is also an effective adjunctive treatment to MOUD. Funding entities typically restrict the use of CM, however, to only a subset of these conditions for various programmatic or statutory reasons. Several HHS grantees identified such restrictions as a barrier to implementing CM. Since establishing a new CM program often requires significant time, resources, and redesign of clinical workflows, grantees noted that clinicians were more hesitant to undertake such investments when the application of CM was limited to a narrower set of SUDs. Other stakeholders noted that, as a result of changing substance use patterns and increasing adulterants in the drug supply, clinicians are increasingly encountering polysubstance use. Under these conditions, stakeholders have expressed concern that narrowly limiting the application of CM to specific types of SUDs means that many people who could benefit from CM would not be eligible to receive it, especially since CM can be, and is, used successfully for people who engage in polysubstance use.

## Knowledge, Attitudes, and Stigma Related to CM

As discussed earlier in this report, stigmatizing attitudes and inaccurate beliefs about CM are common among clinicians, community stakeholders, and even clients -- and can also pose barriers to implementation. Among clinicians, some express ethical concerns related to the use of incentives, viewing them as coercive, manipulative, or even fostering dependence on external rewards (102, 106), even despite evidence that CM does not diminish internal motivation for recovery (96). Other clinicians might have limited understanding or knowledge of CM, preventing proper integration and execution of CM programs (107). Furthermore, the belief that other established treatment approaches are already sufficient can deter clinicians from adopting new evidence-based practices, including CM (108). HHS grantees also noted that stigma and misinformation about CM among non-clinical staff working in organizations seeking to implement CM can be a barrier to adoption.

HHS grantees also identified a lack of understanding of CM, negative attitudes toward incentives, and broader stigma toward people who use substances as barriers to obtaining adoption and acceptance from community stakeholders in areas where CM programs are being implemented. Finally, grantees noted that clients themselves might have negative biases about receiving incentives for recovery, or skepticism of the effectiveness of CM.

## Importance of Strict Fidelity to Treatment Protocols

Fidelity refers to the degree to which an intervention is delivered as intended by its developers (109). High fidelity is essential for achieving the desired outcomes of an intervention, but for many interventions, maintaining fidelity can be difficult in real-world clinical settings (110), and CM is no exception. As discussed in detail in a subsequent section of this report (“Opportunities to Improve Access and Quality and Strengthen Program Integrity”), strict fidelity to treatment protocols is particularly important for CM in order to ensure effectiveness, safeguard program integrity, and prevent negative unintended consequences. This is because deviation from evidence-based protocols might lead to reinforcement of negative or harmful behaviors, rather than the desired positive behaviors (see section on “Incentive Timing” for an example). Because CM treatment protocols differ considerably from many other behavioral therapies, however, promoting fidelity may require redesign of clinic workflows, additional investments in quality assessment and assurance processes, staff training, and ongoing provider supervision and support (40, 111–113). These changes may be costly or challenging to implement and can therefore be a barrier to wider adoption of CM and delivery of high-quality CM (103).

## Limited Access to Robust Training and Mentoring Programs

Provider training and ongoing support and supervision are noted by experts to be essential elements of maintaining fidelity to CM treatment protocols (112). Studies have demonstrated that in addition to equipping providers with information on the principles of CM, detailed education on the implementation of CM in clinical settings and ongoing training opportunities are necessary to promote adoption of evidence-based CM (2, 114). Real-world CM programs vary, however, in the extent to which they incorporate provider training and continued supervision and support (5). This has been attributed to limited access to training on CM principles and techniques (42), as well as to limited information about the specific format that education on CM should take (61).

## Workforce Challenges

A number of HHS grantees identified broader behavioral health workforce challenges as also being a barrier to implementing CM. They noted that implementing CM with fidelity can be labor-intensive, not only for the clinicians who deliver the intervention, but also for non-clinical staff who help support program administration, monitoring, and quality assurance. In the current environment of workforce shortages, recruiting sufficient staff to implement CM with fidelity can therefore pose a challenge in certain communities.

h HHS agencies established a $75 annual value limit for grant-funded CM incentives based on OIG guidance related to gifts of nominal value that are permissible under the Beneficiary Inducements CMP. This guidance includes a $75 annual, aggregate limit per beneficiary on the value of gifts (i.e., in-kind items or services, not cash payments), among other restrictions. Although this guidance does not directly pertain to CM incentives, OIG has noted that CM incentive arrangements may implicate the federal anti-kickback statute, the Beneficiary Inducements CMP, or both (101). However, CM incentives that implicate one or both of these statutes are not necessarily illegal; compliance depends on the specific facts of each arrangement, which must be analyzed on a case-by-case basis unless the arrangement satisfies an existing safe harbor or exception. Therefore, agencies have opted to retain the $75 annual value limit to prevent cases of non-compliance with the Beneficiary Inducements CMP. For more information about OIG’s guidance on gifts of nominal value, visit https://www.hhs.gov/guidance/sites/default/files/hhs-guidance-documents/2006053221-hi-oigpolicystatementgiftsofnominalvalue.pdf.

i As previously noted, more recent studies (e.g., Rash, 2023 (37)) indicate that higher incentive amounts may be necessary to preserve the effectiveness of CM in settings where other economic factors (e.g., cost of living) limit the range of items for which incentives can be redeemed.

j In SAMHSA’s SOR grant program, states are the grant recipients that then allocate funds among government and non-governmental entities.