# WHAT IS CONTINGENCY MANAGEMENT?

CM is a behaviorally based clinical intervention where tangible reinforcers (e.g., gift cards, vouchers, prizes, other items of value) are given to clients contingent on objective evidence of a specific, incentivized behavior(s) (i.e., evidence obtained from standard, unbiased measures that can be independently verified, such as drug test results and attendance records) (2). When used for SUDs, CM incentives are a form of treatment because their purpose is to reinforce abstinence from substances, and reinforce other recovery-oriented behaviors, such as attendance at SUD treatment sessions (e.g., group therapy, counseling) and medication adherence (21, 34, 35). Receiving incentives for reducing substance use or engaging in SUD treatment can help people become more aware and self-accountable regarding their substance use, further supporting their recovery (36).

## Treatment Approach

Before starting CM, the clinician will discuss the goals of CM with the client and how it works. If clinicians have the resources to offer different kinds of incentives (e.g., vouchers or gift cards redeemable for specific needs, such as food or transportation), they should ask the client which kinds of incentives are most appealing and most likely to motivate the client to reduce their substance use and/or continue engaging in treatment (37). A typical CM session consists of the following elements (24, 38):

- Brief discussion of any substance use and cravings since the initial visit or prior CM session.
- If the previous session was missed, a brief discussion of whether the absence was unexcused or excused (because this determination affects the schedule of reinforcement).
- Verification that the incentivized behavior was achieved.
  ○ Where abstinence is the incentivized behavior, this is confirmed through a rapid POC drug test.
  ○ Where treatment attendance is the incentivized behavior, this is confirmed through review of treatment attendance records.
  ○ Where adherence to long-acting MOUD is the incentivized behavior, this is confirmed through administration of the medication by a clinician and clinical documentation of administration.
- If the incentivized behavior was achieved, incentives are provided using one of the reinforcement methods described below.
- If the incentivized behavior was not achieved, no incentive is provided.
- Brief discussion of how the individual plans to use the incentives, with positive verbal reinforcement and reminder of upcoming CM sessions.

The two evidence-based reinforcement methods most commonly used in real-world treatment protocols are prize-based and voucher-based CM, in which incentives are assigned monetary values, but are not disbursed as cash.

1. [underlined: Prize-based]: This is exemplified in the “fishbowl” model, in which people demonstrating the incentivized behavior receive draws from a fishbowl, either in a set number (e.g., one draw for each substance-negative drug test) or with an escalating schedule (e.g., one draw for the first negative sample, two draws for the second consecutive negative sample, three draws for the third, and so on) (37, 39). A typical fishbowl comprises 500 prize tickets, about half of which have monetary value and half of which have no monetary value (the latter prize tickets typically state “good job”). Prize amounts indicated on prize tickets that have monetary value vary in magnitude, typically from $1 to $100,^c^ with the majority of such prize tickets showing the smallest magnitude ($1), a smaller number providing larger magnitude (e.g., $20) prizes, and one slip in the bowl for the maximum prize ($100). Prize amounts are then provided to the person in the form of gift certificates or in-kind prizes with the corresponding value. When the incentivized behavior is not achieved, no draws are received; and in protocols with an escalating draw schedule, draws are “reset” to one for the next time the incentivized behavior is achieved. Prize tickets are replaced after each draw so the probability of receiving a prize ticket with monetary value is always the same across clients for any draw.
2. [underlined: Voucher-based]: Voucher-based methods offer a set reinforcement amount when people successfully complete incentivized behaviors (e.g., $2 per substance-negative drug test) and typically escalate by a prescribed amount (e.g. $0.50), with repeated performance of the behavior (e.g., $2 for first negative drug test, $2.50 for second consecutive negative drug test, $3 for third, and so on), but “reset” to $0 when the incentivized behavior is not achieved (e.g., a substance-positive drug test).^d^ Variations on the voucher-based protocol in which “points” are received after successful completion of incentivized behaviors, which can later be exchanged for items or services of value, have also been found to be effective (40).

Both prize-based and voucher-based protocols generate moderate effect sizes on treatment outcomes with no differences in outcomes noted in head-to-head comparisons of these two methods (41–44). Examples of efficacious study protocols are available through the NIDA Clinical Trials Network dissemination library.^e^

## Evidence Base for CM for Treating SUDs

CM has three decades of research demonstrating its long-term efficacy for treating a variety of SUDs, including stimulant, opioid, cannabis, alcohol, and tobacco use disorders, as well as concurrent SUDs (3, 14, 35, 42, 45–50). In studies comparing CM with other psychosocial interventions for SUD (e.g., cognitive behavioral therapy [CBT], motivational enhancement therapy),^f^s CM produced significantly higher abstinence rates over the course of treatment, higher retention in treatment, and higher abstinence self-efficacy (51–55). CM is also effective in producing abstinence that persists at least one year following treatment, either alone or in combination with other evidence-based behavioral therapies for SUDs (3, 4, 49). CM is effective in diverse client populations, including people with concurrent mental disorders, people experiencing homelessness, justice-involved populations, and racially and socioeconomically diverse populations (56–64).

In addition to SUDs, CM has been shown to effectively treat multiple different medical conditions through encouraging and reinforcing health-promoting behaviors. For example, CM has been used to improve adherence to blood-glucose monitoring among young people with diabetes, and to improve mental health outcomes among elementary school-aged children (65, 66). Researchers have noted, however, that there are unique aspects of SUD pathology -- such as how SUDs affect the brain’s reward system and decision-making processes -- that might contribute to the efficacy of CM in treating SUDs in particular (67).

SUDs co-opt and disrupt brain circuitry involved in learning (or reinforcement of) behaviors that produce a reward, such as feelings of pleasure or relief from pain. As a result of this, in people with SUD, the immediate positive feelings from substance use continue to become reinforced by the brain’s reward circuitry over time, as well as the cues associated with past substance use -- in other words, people, places, or feelings can become linked with past substance use in ways that motivate people to seek substances in the future when they are exposed to those cues. As SUD develops, there is progressive disruption of the brain’s reward circuitry: the brain becomes more sensitive to the cue-driven expectation of substances and their rewarding effects. At the same time, the brain becomes less sensitive to the actual rewards from substance-taking (e.g., euphoria, positive physical sensations), as well as to the satisfaction from non-substance rewards (e.g., food, prizes, previously fulfilling activities) (68, 69). There is also evidence that people with SUD have changes to their brains’ self-regulation circuitry (anatomically in the prefrontal cortex) that normally helps us avoid risky or self-destructive behaviors, resist temptation (such as taking substances), and delay gratification (69, 70).

CM is thought to help repair these disrupted brain circuits, and thus to help people with SUD recover in several ways. First, by offering positive reinforcement for abstinence and other recovery-related activities (e.g., treatment attendance, medication adherence) via concrete and immediate incentives, CM can compete with and displace the reinforcement associated with substance use (71, 72), helping to reorient the brain’s reward circuitry toward non-substance rewards (73). In doing so, CM also engages clients’ decision-making processes in a way that improves their ability to conceptualize and act on non-substance options that produce positive outcomes (74). As noted above, there is evidence that people with SUDs experience changes to their brains’ self-regulation circuitry that lead to a stronger preference for immediate rewards over delayed gratification (termed “delay discounting”) -- the immediacy with which CM incentives are provided after achieving a desired behavior is therefore part of what makes the treatment effective in reinforcing healthful behaviors, relative to substance use. Finally, CM also helps the brain to heal through the treatment’s impacts on abstinence from substances. Many studies show that abstinence from substances can at least partially reverse the substance-induced deficits in the brain’s reward and self-regulation circuits. In people with stimulant use disorders, for example, abstinence is associated with a recovery of some measures of normal brain activity (75, 76), as well as a recovery of brain gray-matter tissue in self-regulation circuitry (70). There is evidence from both brain imaging and studies of brain neurotransmitter activity that among people with cocaine use disorder who were able to reduce their substance use after treatment with CM, there is some recovery of normal brain activity in the reward and self-regulation networks that have been disrupted by addiction (77, 78).

The evidence base for CM for specific SUDs is described below:

- [underlined: Stimulant use disorder]: CM is effective at reducing stimulant use and is among the most effective available treatments for stimulant use disorder, for which there are no FDA-approved medications (2–4). CM is superior to other psychosocial interventions for stimulant use disorder -- it is about twice as effective as alternative treatments such as CBT, counseling, and motivational interviewing (79). While CM is effective as a standalone treatment for stimulant use disorders, its efficacy may be enhanced when combined with other evidence-based treatments such as CRA (45).
- [underlined: Opioid use disorder (OUD)]: FDA-approved MOUD (i.e., buprenorphine, methadone, extended-release naltrexone) are highly effective first-line therapies (80), so current clinical guidelines note that CM should not be considered a substitute for MOUD and should not be used as a first-line intervention for OUD. CM can, however, be an effective adjunct to MOUD. An analysis of 60 clinical trials conducted over more than three decades found that for people receiving MOUD, CM performed better than standard care for producing MOUD adherence and end-of-medication abstinence from opioids as well as polysubstance use (81).
- [underlined: Cannabis use disorder]: CM has moderate effectiveness in reducing cannabis use and decreasing the severity of cannabis use disorder, when implemented alongside CBT and/or motivational enhancement therapy (82).
- [underlined: Alcohol use disorder]: CM is an effective treatment for alcohol use disorder, with studies identifying substantial reductions in both the frequency and amount of alcohol consumption, as well as significant increases in abstinence (39, 61, 83–86).
- [underlined: Tobacco use disorder]: CM is effective in increasing smoking cessation rates. In an analysis of 30 clinical trials, participants who received CM for tobacco smoking cessation were 50% more likely, on average, to discontinue smoking by 6 months than those who received usual care and/or a cessation intervention without contingent rewards (48). Another analysis included in this study found that the impact was highest in studies of pregnant women: those who received CM for smoking cessation were more than twice as likely to quit and remain smoke-free 6 months after childbirth, compared with those treated through usual care and/or non-contingent smoking cessation programs. A systematic review also found that among pregnant women, CM was superior to motivational interviewing, CBT, mindfulness, and hypnosis in reducing smoking (87).

There are important differences by SUD in the specific types of incentivized behaviors (e.g., abstinence, treatment attendance) that are recommended for CM protocols under current clinical guidelines -- this is discussed further below under “Incentivized Behaviors.”

By reducing substance use and improving engagement in SUD treatment, CM -- when provided alone and in conjunction with other interventions -- has also been shown to reduce the complications of substance use and promote better health outcomes, including improved cardiovascular health among individuals with stimulant use disorder (as evidenced by lower coronary plaque burden and lower levels of plasma endothelin-1, a biomarker for cardiovascular disease) (88), a reduction in high-risk sexual behaviors among people who use drugs (55), and suppression of HIV among men with HIV and stimulant use disorder (89). CM is also associated with positive social outcomes that are important to SUD recovery; one study found that, in addition to reducing stimulant use and improving other psychiatric-related outcomes, CM led to improvements in employment status and in family and social relationships (54).

## Case Study: The Veterans' Health System's Successful Nationwide CM Program

The VA has included CM among its evidence-based SUD treatment options since 2011, and as of 2019, more than 100 VA medical centers offered CM (26), representing the largest-scale implementation of CM to date (22). Most participating centers offer abstinence as an incentivized behavior, while a smaller proportion offer treatment attendance. All programs in the VA system employ the “fishbowl” (i.e., prize-based) method to offer incentives that vary in scope and size (see “Using Evidence-Based Treatment Protocols” below), from a simple note saying, “Good job!” to prize coupons valued at $1 to $100.^g^ The average value of incentives over 12 weeks is equivalent to approximately $200 per veteran, and prize coupons can be redeemed for merchandise at any Veterans Canteen Service retail store, cafeteria, or coffee shop. Published VA protocols include check-ins 2–3 times weekly, with use of onsite rapid POC tests to check for abstinence and offer incentives immediately following a negative test (21). A 2018 study found that the majority of participating VA centers demonstrated a high degree of fidelity to evidence-based practices for CM (21). As of the publication of this report, more than 6,300 veterans have received CM through the VA. Among the nearly 82,000 urine samples that these veterans collectively submitted for abstinence-based CM, more than 90% have tested negative for the target substance (most commonly stimulants, and sometimes cannabis), comparable with rates observed in clinical trials (22, 90).

Several features of the VA’s nationwide initiative have contributed to the high levels of uptake by practitioners, high quality of CM services, and positive client outcomes. These include a robust CM-specific training curriculum for practitioners; pre-implementation planning calls for VA sites interested in offering CM to prepare for and support the design of effective interventions; routine assessment of service quality and fidelity to evidence-based practices; and post-implementation CM coaching calls to further enhance quality and fidelity (21, 22, 24, 25).

The VA’s experience and results are a striking indicator of the potential value of implementing CM more broadly across the nation’s health care system, and for the potential recovery of people living with very difficult-to-treat SUDs.

CM works by helping people to make health-promoting changes in their lives that would otherwise be very difficult because of the impacts of SUDs on the brain. Attitudes that people with SUDs should simply be able to stop using substances are prevalent, as are opinions that substance use reflects a personal or moral failing and that people with SUDs are therefore less deserving of treatment and recovery supports. But these views are often shaped by stigma and a misunderstanding of the scientific evidence on how untreated SUDs affect the brain. Chronic substance use can lead to profound neurobiological changes that disrupt the brain’s reward system and impair decision-making abilities, which collectively reinforce continued substance use (69, 70). Without addressing these harmful effects of substance use through treatment and recovery services, people with SUDs face substantially greater challenges than the general population in pursuing health-promoting behaviors. CM addresses this by helping to recalibrate the brain’s reward system toward recovery-related behaviors (e.g., abstinence, treatment attendance, medication adherence) through incentives that make these behaviors more immediately and concretely rewarding (71–74).

CM holds people accountable for meeting their recovery goals, including reduced substance use. CM reinforces recovery-related behaviors that are in the client’s best interest and holds individuals accountable for meeting recovery goals. In abstinence-based CM protocols, people do not receive an incentive unless they test negative for the target substance. In CM protocols that reinforce treatment attendance or medication adherence, people do not receive an incentive unless they engage in treatment.

Abstinence-based CM protocols mitigate the likelihood of diversion. The risk of clients diverting their incentives toward obtaining substances is low; for example, one study found that clients who received cash (which lacks diversion controls recommended by HHS later in this report) as an incentive did not increase their substance use, compared with clients who received non-cash incentives (91). Meanwhile, abstinence-based CM protocols mitigate the likelihood of diversion because clients who use a target substance will not receive an incentive after a positive test, and in CM protocols that escalate the value of incentives, their incentive amount in subsequent CM sessions could reset to a lower value. Nonetheless, HHS recommends various safeguards to prevent diversion by clients or staff and promote program integrity, such as adhering to evidence-based treatment protocols; maintaining proper clinical documentation; implementing appropriate accounting and security measures; and disallowing certain incentive types, such as cash payments and unrestricted cash equivalents (further discussion of recommended restrictions on incentive types occurs later in the report).

The abstinence effects of CM can last even after the treatment is completed. Studies have consistently found that the effects of CM on abstinence persist after treatment is completed (49). Furthermore, CM is among the most effective treatments for promoting lengthier periods of abstinence during treatment, which is associated with a greater likelihood for long-term abstinence following treatment (44, 92–95). In addition, evidence has consistently demonstrated that external reinforcement of recovery-related behaviors does not diminish internal motivation (96). CM reinforces the patient’s efforts at living without the target substance and the longer that period, the greater the likelihood that the patient will begin to experience reinforcements aside from CM to sustain their recovery.

c While these are typical ranges reported in the research literature over the years, more recent studies (e.g., Rash 2023 (37)) have noted that higher incentive amounts may be necessary to preserve the effectiveness of CM in settings where other economic factors (e.g., cost of living) may limit the range of items for which lower-value prize tickets in the $1-$2 range can be redeemed. VA, for example, is raising the value of small prizes from $1 to $3 in its prize-based protocol.

d The incentive amounts here are provided as an example -- larger incentive amounts have also been used in voucher-based protocols.

e For more information, please visit http://ctndisseminationlibrary.org.

f CBT helps individuals to “learn to identify and correct problematic behaviors by applying a range of different skills that can be used to stop drug [use] and to address a range of other problems that often co-occur with it.” Motivational enhancement therapy “helps individuals resolve their ambivalence about engaging in treatment and stopping their drug use… [by evoking] rapid and internally motivated change.” For more information, see NIDA’s Principles of Drug Addiction Treatment: A Research-Based Guide (Third Edition) at https://archives.nida.nih.gov/sites/default/files/podat-3rdEd-508.pdf.

g As discussed later in this document, VA plans to increase the value of these prize coupons.