# INTRODUCTION

The drug overdose crisis continues to worsen, with provisional data predicting over 110,000 overdose deaths in 2022 (15). Many overdoses involve polysubstance use (16). Synthetic opioids such as fentanyl remain the major driver of overdose deaths, but stimulants, particularly methamphetamine, also play a prominent role: in 2022, based on provisional data, cocaine was involved in nearly one in four overdose deaths, while psychostimulants with abuse potential (e.g., methamphetamine) were involved in nearly one in three overdose deaths (17). Stimulants are also the fastest-growing category of substances involved in overdose deaths. Between 2020 and 2021, the rate of deaths involving psychostimulants with abuse potential, such as methamphetamine, increased 34% -- a more rapid rate of increase than for overdose deaths involving opioids (18). There are currently no FDA-approved medications to treat stimulant use disorders, and naloxone -- the opioid overdose reversal medication that has saved countless lives – does not reverse stimulant overdoses (19, 20). The most effective available treatment for stimulant use disorder is CM, a behaviorally based clinical intervention.

CM is an evidence-based psychosocial therapy for the treatment of stimulant use disorder, as well as a variety of other SUDs, that is supported by three decades of research (2–4, 21–25). It involves providing incentives to people to reinforce desired behaviors that promote recovery from SUDs, such as abstinence from substance use, SUD treatment attendance, and adherence to medications for SUDs. VA began implementing CM for stimulant use disorder and other SUDs in 2011, and now has a successful nationwide program that has been well described in the research literature (26). CM is currently permitted under several HHS grant programs (e.g., Substance Abuse and Mental Health Services Administration’s [SAMHSA’s] State Opioid Response (SOR) and Tribal Opioid Response Grants, and the Health Resources and Services Administration's Rural Communities Opioid Response Program’s Psychostimulant Support Program). In 2021, the Centers for Medicare & Medicaid Services (CMS) approved California as the first state to offer Medicaid coverage of CM for stimulant use disorder through a Section 1115 demonstration (27); in June 2023, CMS also approved Washington State’s request to offer Medicaid coverage of CM for SUDs through its Section 1115 renewal. Delaware, Montana and West Virginia have submitted requests for coverage in their respective Section 1115 demonstrations.^a^ In addition, Community Reinforcement Approach (CRA)^b^ + Vouchers, which combines a community reinforcement approach with a voucher component (i.e., CM) that provides incentives for remaining in treatment and sustaining cocaine abstinence, has been rated as a promising practice by Title IV-E Prevention Services Clearinghouse, and is therefore a permitted use of Title IV-E Prevention Service Program funds (28, 29).

Despite CM’s great potential and demonstrated effectiveness in improving the health and well-being of many people with SUDs, this proven treatment remains underutilized (5–8). Expanding access to high-quality CM services for the treatment of SUDs represents an important opportunity to accelerate efforts to address the overdose crisis, as well as the other substantial public health harms and costs related to untreated SUDs (e.g., cancers, infectious diseases, cardiovascular disease, oral health, cirrhosis of the liver, accidental injury) (30). State officials, health care delivery organizations and providers are eager to expand effective treatments for people who have had few options and have expressed the need for guidance and other policy actions to support broader implementation of CM in particular (9, 31–33).

In recognition of this opportunity, and to guide efforts by federal, state, local governments and other stakeholders, Section 4127 of the Consolidated Appropriations Act, 2023 (42 U.S.C. § 1320a-7d(a)(3)(B)), included a requirement for the Secretary and the Inspector General to “submit to Congress recommendations... for improving access to evidence-based contingency management interventions while ensuring quality of care, ensuring fidelity to evidence-based practices, and including strong program integrity safeguards that prevent increased waste, fraud, and abuse and prevent medically unnecessary or inappropriate items or services reimbursed in whole or in part by a federal health care program.”

To respond to this provision, the HHS Workgroup on Implementation Strategies for Contingency Management, which included representatives from OIG who provided technical assistance in the Workgroup and on this report, has prepared this Report to Congress, which discusses opportunities and considerations for entities overseeing CM implementation, including regulators at the federal, state, Tribal, local and territorial levels; funders (e.g., grant making agencies, insurance companies); health care organizations; and health care providers. This report was informed by the published literature on CM for the treatment of SUDs and expert perspectives based on CM implementation experience at the time of issuance. The report also includes the perspectives of HHS and VA subject matter experts and insights from prior listening sessions with leading CM researchers, practitioners with experience implementing CM in real-world settings (including HHS grantees), professional associations, and people with lived experience, as well as contributions from OIG to address potential or perceived fraud and abuse concerns. Importantly, as the research evidence for CM, implementation experience, and the technology underlying components of CM interventions (e.g., drug tests, mobile applications) evolve, the opportunities and considerations highlighted in this report should be updated accordingly.

a For more information about Section 1115 demonstrations, visit https://www.medicaid.gov/medicaid/section-1115-demonstrations/index.html.

b CRA “uses a range of recreational, familial, social, and vocational reinforcers, along with material incentives, to make a non-drug-using lifestyle more rewarding than substance use.” For more information, see National Institute on Drug Abuse’s (NIDA’s) Principles of Drug Addiction Treatment: A Research-Based Guide (Third Edition) at https://archives.nida.nih.gov/publications/principles-drug-addiction-treatment-research-based-guide-third-edition.