# References

1 Substance Abuse and Mental Health Services Administration (SAMHSA), Center for Behavioral Health Statistics and Quality. Key substance use and mental health indicators in the United States: Results from the 2019 National Survey on Drug Use and Health. HHS Publication No. PEP20-07-01-001, NSDUH Series H-55. 2020. Accessed April 27, 2021. https://www.samhsa.gov/data/sites/default/files/reports/rpt29393/2019NSDUHFFRPDFWHTML/2019NSDUHFFR090120.htm.
2 Bishop TF, Seirup JK, Pincus HA, Ross JS. Population of US Practicing Psychiatrists Declined, 2003–13, Which May Help Explain Poor Access to Mental Health Care. Health Affairs. 2016; 35(7): 1271–1277. doi:10.1377/hlthaff.2015.1643.27385244
3 Thomas KC, Ellis AR, Konrad TR, Holzer CE, Morrissey JP. County-level estimates of mental health professional shortage in the United States. Psychiatr Serv. 2009; 60(10): 1323–1328. doi:10.1176/ps.2009.60.10.1323.19797371
4 Health Resources and Services Administration (HRSA), Health Workforce. Behavioral Health Workforce Projections, 2017–2030. https://bhw.hrsa.gov/sites/default/files/bureau-health-workforce/data-research/bh-workforce-projections-fact-sheet.pdf.
5 Smith CD, Balatbat C, Corbridge S, Implementing optimal team-based care to reduce clinician burnout. 2018. https://pdfs.semanticscholar.org/180a/263cef0661c2b9c330d46599d1fa0c86c3c4.pdf.
6 Parks J, Kern J, Desorrento L. Optimizing the Psychiatric Workflow Within a Team-Based Care Framework. 2021:21. https://www.thenationalcouncil.org/wp-content/uploads/2021/01/010521_Psychiatric_Workflow_Team-based_Care_Toolkit.pdf?daf=375ateTbd56.
7 Mitchell P, Wynia M, Golden R, Core principles & values of effective team-based health care. 2012, October. Accessed May 3, 2021. https://nam.edu/wp-content/uploads/2015/06/VSRT-Team-Based-Care-Principles-Values.pdf.
8 Reiss-Brennan B, Brunisholz KD, Dredge C, Association of Integrated Team-Based Care With Health Care Quality, Utilization, and Cost. JAMA. 2016; 316(8): 826–834. doi:10.1001/jama.2016.11232.27552616
9 Center for Healthcare Q, Payment R. Accelerating the Implementation of Value-Based Care and Payment. 2016. http://www.nrhi.org/uploads/2016_nationalpaymentreformsummit.pdf.
10 Isvan N, Gerber R, Hughes D, Battis K, Anderson E, O'Brien J. Credentialing, Licensing, and Reimbursement of the SUD Workforce: A Review of Policies and Practices Across the Nation. 2019. https://aspe.hhs.gov/sites/default/files/migrated_legacy_files//193271/CLRSUDWorkforce.pdf.
11 Shern D. Issue Brief Financing Coordinated Specialty Care for First Episode Psychosis: A Clinician/Advocate’s Guide. 2020. https://smiadviser.org/wp-content/uploads/2020/08/CSC-Issue-Brief_v2-081320.pdf.
12 National Institute of Mental Health (NIMH). Coordinated Specialty Care for First Episode Psychosis. https://web.archive.org/web/20210709213701/https:/www.nimh.nih.gov/health/topics/schizophrenia/raise/csc-for-fep-manual-ii-implementation-manual_147093.pdf.
13 Chan V, Derenne J. Transition-Age Youth Mental Health Care: Bridging the Gap Between Pediatric and Adult Psychiatric Care. Springer Nature; 2021: 485.
14 Bao Y, Papp MA, Lee R, Shern D, Dixon LB. Financing Early Psychosis Intervention Programs: Provider Organization Perspectives. Psychiatr Serv. October 1, 2021; 72(10): 1134–1138. doi:10.1176/appi.ps.202000710.33657841
15 Pinals DA. Crisis Services: Meetings Needs, Saving Lives. 2020. https://www.nasmhpd.org/sites/default/files/2020paper1.pdf.
16 Hogan MF, Goldman ML. New Opportunities to Improve Mental Health Crisis Systems. Psychiatr Serv. 2021; 72(2): 169–173. doi:10.1176/appi.ps.202000114.32988327
17 Services CfMaM. New Medicaid Option Promotes Enhanced Mental Health, Substance Use Crisis Care. https://www.cms.gov/newsroom/press-releases/new-medicaid-option-promotes-enhanced-mental-health-substance-use-crisis-care.
18 Parekh R. Child and Adolescent Telepsychiatry. Accessed January 27, 2022. https://www.psychiatry.org/psychiatrists/practice/telepsychiatry/toolkit/child-adolescent/introduction.
19 Washington State Mental Health Integration Program (MHIP). https://aims.uw.edu/mental-health-integration-program-mhip.
20 Alliance for Addiction Payment Reform. ARMH-APM Model. https://incentivizerecovery.org/armh-apm-model/.
21 AWARE Recovery Care. In-Home Private Approach to Addiction Care. https://www.awarerecoverycare.com/in-home-recovery.
22 Richardson J, Rosenberg L. Peer Support Workers in Emergency Departments: Engaging Individuals Surviving Opioid Overdoses--Qualitative Assessment. 2018. https://www.thenationalcouncil.org/wp-content/uploads/2018/12/Peer-Support-Workers-in-EDs-Issue-Brief.pdf?daf=375ateTbd56.
23 Substance Abuse and Mental Health Services Administration (SAMHSA). Use of Medication-Assisted Treatment in Emergency Departments Vol. HHS Publication No. PEP21-PL-Guide-5. 2021. https://store.samhsa.gov/sites/default/files/SAMHSA_Digital_Download/pep21-pl-guide-5.pdf.
24 Reif S, Brolin MF, Stewart MT, Fuchs TJ, Speaker E, Mazel SB. The Washington State Hub and Spoke Model to increase access to medication treatment for opioid use disorders. J Subst Abuse Treat. 2020; 108: 33–39. doi:10.1016/j.jsat.2019.07.007.31358328
25 Miele GM, Caton L, Freese TE, Implementation of the hub and spoke model for opioid use disorders in California: Rationale, design and anticipated impact. J Subst Abuse Treat. 2020; 108: 20–25. doi:10.1016/j.jsat.2019.07.013.31399272
26 Brooklyn JR, Sigmon SC. Vermont Hub-and-Spoke Model of Care for Opioid Use Disorder: Development, Implementation, and Impact. J Addict Med. 2017; 11(4): 286–292. doi:10.1097/ADM.0000000000000310.28379862
27 Stoller KB. A collaborative opioid prescribing (CoOP) model linking opioid treatment programs with office-based buprenorphine providers. Addiction Science & Clinical Practice. 2015; 10(1): A63. doi:10.1186/1940-0640-10-S1-A63.
28 Medicare Learning N. Opioid Treatment Programs (OTPs) Medicare Billing & Payment. 2021. https://www.cms.gov/files/document/otp-billing-and-payment-fact-sheet.pdf.
29 Kaiser Family Foundation. Federal Legislation to Address the Opioid Crisis: Medicaid Provisions in the Support Act. https://www.kff.org/medicaid/issue-brief/federal-legislation-to-address-the-opioid-crisis-medicaid-provisions-in-the-support-act/#:~:text=The%20SUPPORT%20Act%20prohibits%20states%20from%20terminating%20Medicaid,a%20new%20application%20and%20restore%20coverage%20upon%20release.
30 Moses K, Klebonis J. Designing Medicaid Health Homes for Individuals with Opioid Dependency: Considerations for States. 2015.
31 Strategies CfHC. Best Practices for Designing and Implementing Substance Use Disorder (SUD)-Focused Health Homes. 2020. https://www.medicaid.gov/state-resource-center/downloads/best-practices-health-homes-support-act-section-1006a.pdf.
32 Spillman B, Allen E, Spencer A. Evaluation of the Medicaid Health Home Option for Beneficiaries with Chronic Conditions: Annual Report--Year Three. 2015. https://aspe.hhs.gov/sites/default/files/private/pdf/163041/HHOption3.pdf.
33 Raney L. Crack the Codes: State Medicaid Approaches to Reimbursing Psychiatric Collaborative Care. 2020. https://www.chcf.org/wp-content/uploads/2020/09/CrackingCodesMedicaidReimbursingPsychiatricCollaborativeCare.pdf.
34 Carlo AD, Corage Baden A, McCarty RL, Ratzliff ADH. Early Health System Experiences with Collaborative Care (CoCM) Billing Codes: a Qualitative Study of Leadership and Support Staff. J Gen Intern Med. 2019; 34(10): 2150–2158. doi:10.1007/s11606-019-05195-0.31367872
35 National Alliance on Mental Illness. Assertive Community Treatment--Treatment Options. 2017. https://namimn.org/wp-content/uploads/sites/188/2018/05/Assertive-Community-Treatment_TreatmentOptions_2018.pdf.
36 Rosenberg L. Medicare parity: We're not done yet! J Behav Health Serv Res. 2010; 37(3): 283–4. doi:10.1007/s11414-010-9218-7.20480245
37 National Council for Behavioral Health. Hope for the Future: CCBHCs Expanding Mental Health and Addiction Treatment--An Impact Report. 2020. https://www.thenationalcouncil.org/wp-content/uploads/2020/03/2020-CCBHC-Impact-Report.pdf?daf=375ateTbd56.
38 Catalyst N. What are Bundled Payments? 2018. https://catalyst.nejm.org/doi/full/10.1056/CAT.18.0247.
39 Shartzer A, Berenson R, Zuckerman S, Devers K, Moiduddin A. Common Alternative Payment Model (APM) Approaches: Reference Guide. 2020. https://aspe.hhs.gov/sites/default/files/private/pdf/261946/Common-APMs-Reference-Guide.pdf.
40 Carlo AD, Unützer J, Ratzliff ADH, Cerimele JM. Financing for Collaborative Care--A Narrative Review. Curr Treat Options Psychiatry. 2018; 5(3): 334–344. doi:10.1007/s40501-018-0150-4.30083495
41 Health NCfB. Certified Community Behavioral Health Clinics: An Alternative Payment Model for Comprehensive Care Delivery. 2019. https://www.thenationalcouncil.org/wp-content/uploads/2020/08/093019_CCBHCs_AlternativePaymentModel_FactSheet_v2.pdf?daf=375ateTbd56.
42 Brown JD, Urato C, Ogbuefi P. Uptake of Medicare Behavioral Health Integration Billing Codes in 2017 and 2018. J Gen Intern Med. 2021; 36(2): 564–566. doi:10.1007/s11606-020-06232-z.32959345
43 Office of Mental Health. Crisis Intervention Benefit: Mobile Crisis Component Benefit and Billing Guidance. 2019. https://omh.ny.gov/omhweb/bho/docs/mobile_crisis_intervention_guidance.pdf.
44 Edens EL, Donahue CA, Riordan CE. Pilot results of a new model of addiction treatment: managing addiction as a chronic disease. Conn Med. 2014; 78(8): 487–91.25314889
45 Substance Use Disorder: Medicaid Coverage of Peer Support Services for Adults. https://www.gao.gov/assets/gao-20-616.pdf.
46 Partnering with Medicaid Managed Care Organizations to Advance Prevention Priorities under CDC's 6|18 Initiative. 2019. https://www.618resources.chcs.org/wp-content/uploads/2019/08/618-MCO-Engagement-Resource_081619.pdf.
47 Shaw R. Financing Mental Health Crisis Services. 2020. https://www.nasmhpd.org/sites/default/files/2020paper7.pdf.
48 Ranallo PA, Kilbourne AM, Whatley AS, Pincus HA. Behavioral Health Information Technology: From Chaos To Clarity. Health Aff. 2016; 35(6): 1106–1113. doi:10.1377/hlthaff.2016.0013.
49 Best Practices for Designing and Implementing Substance Use Disorder (SUD)-Focused Health Homes. 2020. https://www.chcs.org/media/Best-Practices-for-Designing-and-Implementing-Substance-Use-Disorder-Paper.pdf.