# Acknowledgements

We thank Miku Fujita for her research support throughout the study, and Tami Mark and Sara Karon for reviews of an early version of this report.