# Executive Summary

## ES.1 Why is team-based care vital for behavioral health?

The high prevalence of mental health conditions and substance use disorder in the United States is exacerbated by high levels of unmet service needs. Behavioral health workforce shortages contribute to challenges in accessing behavioral health care. Team-based care is a service approach that typically involves two or more individuals of varying disciplines and backgrounds who work collaboratively to provide coordinated behavioral health care. Team-based care can help alleviate behavioral health workforce shortages by utilizing peers and non-licensed professionals. The additional team members facilitate licensed professionals practicing at the top of their license, thereby increasing capacity and the ability to deliver additional services. However, team-based behavioral health care is often not adequately reimbursed, making it difficult to sustain. The Office of the Assistant Secretary for Planning and Evaluation supported this study to better understand: (1) existing reimbursement mechanisms for team-based behavioral health care models; and (2) strategies that support reimbursement of team-based behavioral health services.

## ES.2 How did we conduct this study?

We conducted an environmental scan to identify common team-based behavioral health care models and their reimbursement mechanisms. We supplemented the environmental scan with interviews with subject matter experts in behavioral health care reimbursement and policies related to reimbursement. Through the environmental scan and interviews, we narrowed our focus to 11 team-based care models. We developed a catalog to compare reimbursement mechanisms and strategies within and across team-based models. The catalog includes publicly available information identifying payer types reimbursing for each model, typical funding sources, and common reimbursement mechanisms.

Following the environmental scan and expert interviews, we conducted case studies of five exemplary models of team-based behavioral health, utilizing different reimbursement mechanisms. We interviewed service providers, health department and other program administrative staff. Our interviews were designed to solicit information on the development and implementation of reimbursement mechanisms to support the models.

## ES.3 What did we find?

Team-based behavioral health models are funded through various mechanisms, often requiring grant funding to make up the short falls in billable services relative to the total service costs. Reimbursement rates often do not cover billable providers’ total costs of team-based care, and vital team members, like peer support specialists and care coordinators can be difficult to bill for. Successfully funded team-based care models (i.e., costs for the team were fully reimbursed) often included a flexible reimbursement mechanism that allowed providers to include components that would otherwise be difficult to reimburse in a fee-for-service (FFS) payment system. Team-based behavioral health care continues to face barriers--some components remain unreimbursed or under-reimbursed; uptake of novel billing codes specific to team-based care is low; and some novel reimbursement mechanisms are associated with a single payer while the teams serve a broader patient mix.

## ES.4 What strategies promote team-based care?

State and federal grant funding play a vital role in the development and implementation of novel reimbursement mechanisms. Medicaid waivers and state plan amendments can be used to expand Medicaid service coverage, supporting the flexible inclusion of team-based care components. The establishment and uptake of novel FFS billing codes with service definitions that included team-based activities is a strategy with potential to increase needed reimbursement across all payers, though to date that uptake is often low. Finally, incorporating the financing for team-based care into the payment structure, as for example with bundled rates or per member per month payments, can create the necessary flexibility to support team-based care.

## ES.5 Conclusions

Team-based care is an established approach for addressing gaps in health care service delivery and has the potential to alleviate workforce shortage challenges by allowing clinicians to practice at the top of their license. But for these approaches to be sustainable, they need reimbursement mechanisms that cover all team members and team-based activities, often not covered by traditional FFS mechanisms. Bundled payments or FFS billing codes that have been enhanced to include team-based activities have been designed to cover the costs of team-based care but are not widespread. Strategies to promote coverage and detailed case studies may provide federal and state administrators with guidelines for how to successfully expand and sustain team-based behavioral health care.