# Acronyms

The following acronyms are mentioned in this report and/or appendix.

ACT: Assertive Community Treatment
APM: Alternative Payment Model
ARMH: Addiction Recovery Medical Home
BH: Behavioral Health
BHH: Behavioral Health Home
CCBHC: Certified Community Behavioral Health Clinic
CMA: Care Management Agency
CMS: Centers for Medicare & Medicaid Services
CoCM: Collaborative Care Model
COE: Center of Excellence
COVID-19: Novel Coronavirus
CPT: Current Procedural Terminology
CSC: Coordinated Specialty Care
ED: Emergency Department
EHR: Electronic Health Record
FFS: Fee-For-Service
HH+: Health Home Plus
HIPAA: Health Insurance Portability and Accountability Act
HIT: Health Information Technology
HRSA: Health Resources and Services Administration
MAT: Medication-Assisted Treatment
MCO: Managed Care Organization
MCT: Mobile Crisis Team
MH: Mental Health
MOUD: Medication for Opioid Use Disorder
OBOT: Office-Based Opioid Treatment
OHH: Opioid Health Home
OMH: New York Office of Mental Health
OMHSAS: Pennsylvania Office of Mental Health and Substance Abuse Services
OTP: Opioid Treatment Program
OUD: Opioid Use Disorder
PCP: Primary Care Provider
PMPM: Per Member Per Month
PPS: Prospective Payment System
PSYCKES: Psychiatric Services and Clinical Knowledge Enhancement System
SAMHSA: Substance Abuse and Mental Health Services Administration
SMI: Serious Mental Illness
SPA: State Plan Amendment
SUD: Substance Use Disorder
TCM: Targeted Case Management