# 6. Conclusions

Team-based behavioral health care occurs across a variety of service models and has the potential to mitigate behavioral health provider shortages while providing effective care. However, these models require innovative reimbursement approaches to address gaps in traditional FFS reimbursement. Many team-based care models lack sustainable reimbursement mechanisms to adequately cover care coordination, patient outreach, on-call availability, and specific providers such as peer support specialists or behavioral health care coordinators. Lack of sustainable reimbursement was especially common for MCTs and psychiatric teleconsult models, both of which must, by definition, be staffed even when not providing face-to-face services.

We identified several innovative strategies for successful reimbursement and explored important barriers and facilitators to implementing these mechanisms. Several key strategies are common in the promotion of successful team-based care and its reimbursement, and those range from high-level (e.g., federal, state) strategies to provider-level strategies. For high-level strategies, reimbursement of team-based behavioral health care is promoted through SPAs and state waivers and through the flexibility in service provision inherent in Medicaid MCOs. Both Medicaid and Medicare have developed billing codes specifically to support team-based care, although uptake and barriers to use remain. Many programs are dependent on braided funding to support elements of team-based care that were not reimbursed through FFS, for example drawing upon federal, state, and local grant funding. Although Medicaid was the primary payer in most of the models, provider and lobbyist groups in several states documented their negotiations with commercial payers to broaden coverage for services such as CSC and ACT, occasionally culminating in a legislative mandate for commercial insurers. When programs developed innovative reimbursement mechanisms, our findings showed the need for grant support in the development stages and the importance of close relationships between administration and providers, to closely map new reimbursement rates to the clinical reality of costs of care.

Team-based behavioral health care models have the potential to alleviate workforce shortage issues by allowing clinicians to practice at the top of their license. Team-based behavioral health care models also allow for different approaches to care that promise to better meet the needs of individuals with complex mental health and SUDs. But for team-based approaches to work and to be sustainable, they need reimbursement mechanisms that cover all team members and team-based activities that traditional FFS mechanisms do not cover. There are clear reimbursement mechanisms, such as bundled payments or team-based FFS billing codes, that cover the costs of team-based care but are not currently widespread. The outlined strategies to promote coverage and detailed case studies should provide federal and state administrators ideas for how to expand coverage for team-based behavioral health care in the future.