# 5. Strategies to Promote Reimbursement of Team-Based Care

Inadequate reimbursement is a barrier to sustained implementation of team-based care. For reimbursement to be sustainable, reimbursement rates should be derived from the actual cost of team-based care accounting for both services provided and team activities. We have seen accurate rate-setting require both up-front investment to collect these rate-setting data, often in the form of grant-funded demonstration projects, as well as collaborative relationships with providers, as provider feedback was instrumental in accurate rate-setting and iterative rate development. Further, sustainable reimbursement depends on availability and standardization of rates across payers. Using the environmental scan, expert interviews, and case studies, we synthesized a range of strategies that promoted the successful and sustained reimbursement of team-based behavioral health care. In this context, a strategy is a step or series of steps that states or programs may take to support reimbursement of team-based behavioral health care.

State and federal grant funding are instrumental in the development of reimbursement rates and the successful implementation of novel reimbursement mechanisms that support team-based behavioral health care. In the environmental scan and catalog, we noted the contribution of state and federal grant funding to the maintenance of MCTs, CCBHCs, psychiatric teleconsult and CSC programs by covering services that are difficult to reimburse for through FFS. Moving beyond maintenance, the case studies indicated that for most reimbursement mechanisms, successful development and implementation depended on grant funding to support start-up and transition. In these cases, funding towards the iterative development of reimbursement rates was associated with rates that aligned more closely with the cost of team-based care provided, and we noted instances where the funding allowed for provider input to be incorporated in rate development.

In pursuit of sustainable reimbursement, states may draw on Medicaid waivers or SPAs as a strategy to expand on services covered by Medicaid state programs. Section 1915(b) waivers allow a state to use savings it achieves through Medicaid managed care to provide additional services that are not already included in the state plan. Medicaid 1115 demonstrations permit the waiving of certain federal Medicaid requirements and allow reimbursement for costs that would not otherwise be eligible for federal funds for experimental, pilot, or demonstration projects that promote Medicaid objectives.^45^ Across models, waivers and SPAs were common strategies to allow for reimbursement of certain elements of team-based care, such as peer support specialists.

Establishing and promoting use of new or enhanced Medicare and Medicaid FFS billing codes with service definitions that support coordinated, team-based care are key to successful reimbursement. CMS and state Medicaid offices are increasingly developing new codes and service definitions that support multidisciplinary teams. Throughout the environmental scan and the case study, we see examples in the CoCM codes, which reimburse for team collaboration, and tailored billing codes for MCTs in New York. Case studies indicated that the development of new codes benefitted from iterative feedback from providers, and that barriers to uptake warrant additional study.

Bundled or PMPM rates more sustainably cover the cost of delivering team-based care. In addition to creating new billing codes that align with components of team-based care, the creation of bundled or augmented rates help to account for the cost of direct care as well as indirect and other team-based costs. The PPS rates applied at demonstration CCBHCs is a striking example for how financing for team-based care can be folded into a payment structure. Other examples include CMS’s recent implementation of a Medicare bundled rate for OTP providers, expanding treatment opportunities for older and disabled adults with OUD.^28^ Establishing bundled payments allows providers the flexibility to provide a set of team-based services under a single rate. In turn, this reimbursement allows providers to deliver services, such as peer support recovery services or client outreach, that would otherwise be difficult to sustain with a lack of coverage under the FFS mechanism. Our findings support the flexibility of bundled rates as a key facilitator of team-based care, especially in SUD treatment settings. In addition, in our case studies focused on bundled payment, there was some indication that bundled and PMPM reimbursement mechanisms were not only more closely aligned with the cost of team-based care, but that they encouraged more clinically appropriate services.

In addition to establishing bundled rates within Medicaid or Medicare to promote flexibility in service provision and team composition, we found that contracting mechanisms in MCOs were another strategy that could be leveraged toward team-based care. Commercial payers and states that have implemented Medicaid managed care can use contracting processes to incentivize the use of non-licensed counselors and peers as a part of team-based care.^46^ Commercial payers and the state Medicaid authority can require providers and MCOs respectively to implement specific care models that rely on peer support and non-licensed counselors, such as ACT or assisted outpatient treatment. Alternatively, commercial payers and states can establish more general guidelines for team-based care, allowing flexible and individualized programs that incentivize the use of teams.

Commercial payers and states also can use contracting processes to hold providers and MCOs accountable for team-based care practices by establishing targets, such as targets for the number of patients who receive peer support services. Commercial payers and states can align these targets to contract payment strategies, either through withhold or incentive arrangements. Payers can also incorporate team-based care elements into contract care management requirements, such as encouraging use of multidisciplinary care teams to support patient needs. Finally, contracts can tie team-based care requirements to performance improvement projects or value-based payment initiatives.

In some cases, state and lobbying efforts with commercial insurers or Medicaid MCOs negotiated coverage for team-based services, or when negotiations were unsuccessful, some states opted to mandate coverage for commercial insurers. Across models and states, there were several instances of providers or lobbying groups negotiating with commercial payers to encourage more inclusive reimbursement for components of team-based care. In addition, state officials were sometimes able to negotiate for coverage across all Medicaid MCOs in their state. In instances when negotiations were unsuccessful, some states elected to mandate program coverage. For example, after efforts to convince commercial insurers to cover ACT and CSC failed in Illinois, the state legislature passed the Children and Young Adult Mental Health Crisis Act which mandates that both ACT and CSC must be covered by commercial insurers for youth under age 26. It further stipulates that both programs be reimbursed through bundled payments and that the team leader’s credentials qualify all team members to be credentialed with the insurer.^11^ Previous research on MCTs indicates that some states have successfully billed for mobile crisis services, though the process was often marred by certification requirements, coverage refusals and lengthy appeals processes, and variation in insurer definitions for what constituted crisis services.^47^

Digital infrastructure can ease the reimbursement process and simultaneously facilitate team-based care. The adoption of digital infrastructure in behavioral health care, such as EHR systems, has lagged behind general health care.^48^ Digital infrastructure has the potential to play a strong role in enhancing team-based care through features like electronic consent, closed-loop electronic referrals toward warm hand-offs, and enhanced integration between behavioral health and other health care providers.^49^ Case study findings also support the role of digital infrastructure in successful billing through integrated checks of billing requirements, in addition to increased connectedness among team members, and between teams and larger repositories of patient data.