# 4. Findings: Case Studies

Based on the environmental scan and reimbursement catalog, we selected five models of team-based behavioral health care as case studies, focusing on programs and providers with innovative approaches to reimbursing for team-based care. Table 4-1 outlines the selected case studies and their reimbursement mechanisms.

Table 4-1 Model Description and Reimbursement Mechanisms, by Case Study

Service Model | Service Model Description | Reimbursement Mechanism
New York’s Mobile Crisis Teams (MCTs) | MCTs of 1 licensed provider, 1 licensed and 1 unlicensed provider, or 2 licensed providers | Enhanced FFS billing under Medicaid MCOs; rates are established by New York’s OMH and are adjusted by team composition (team size, licensing), length of time of service, and region
Montana’s coverage of Medication for OUD (MOUD) | Services related to OUD treatment include provider visits, medication prescription, lab testing, medication distribution, and BH integration management | Bundled payment under Medicaid, reimbursable by OTPs and OBOT
Aware in-home SUD recovery | Services comparable to residential treatment that are provided in-home, including MAT management, peer support, individual and family therapy, and care coordination | Bundled payment through several commercial insurers in multiple states
New York Health Home Plus (HH+) Program | Integrated, coordinated, and transitional care for high-need clients with SMI | OMH reimburses HH+ services using PMPM rates
Pennsylvania Centers of Excellence (COEs) | Outpatient care that integrates OUD treatment with physical health treatment using care management | Pennsylvania’s OMHSAS passes funding to MCOs, which must then direct the funds to a specified list of COEs providers using PMPM rates

## 4.1 New York's Mobile Crisis Team (MCT)

Through its state Medicaid managed care program, New York provides: (1) telephonic triage and crisis response; (2) mobile crisis response; (3) telephonic follow-up; and (4) mobile follow-up for adults and children. Of these four services, this case study focused on the mobile crisis response teams. New York’s Office of Mental Health (OMH) supported the development of enhanced FFS Medicaid codes specific to MCTs. In collaboration with New York’s MCOs, OMH set tiered reimbursement rates for MCTs. There are seven rates, customized by team composition (one licensed provider, two licensed providers, or the most common arrangement: one licensed and one unlicensed provider), location (downstate or upstate), and length of time of service (<90 minutes, 90–180 minutes, >180 minutes).^43^

The seven rates are based on two national procedure codes, H2011 and S9485, which OMH customized to be specific to New York’s needs. Before the development of the enhanced Medicaid FFS codes, most MCTs in New York were entirely dependent on local funding. Billable service flexibility is a strength of the MCT reimbursement through Medicaid. The seven distinct rates allow for context-specific reimbursement. Further, interviewees indicated that New York’s digital infrastructure facilitated the provision of the appropriate MCT, in addition to determining a patient’s insurance coverage. Provider teams use a health information technology (HIT) system called the Psychiatric Services and Clinical Knowledge Enhancement System (PSYCKES), a HIPAA-compliant web-based application that supports team decision-making and care coordination, to determine which team composition is best suited to each crisis call. However, shortages of licensed staff have complicated the process, and the variety of EHR systems has created difficulty in obtaining clients’ demographics and billing information. MCT providers reported difficulty billing commercial insurers, either because providers cannot obtain insurance information from the client, the services exceed the allowable number of units, or the commercial plan does not reimburse MCT services at all. In addition, although OMH successfully negotiated reimbursement for MCTs through Medicaid MCOs, Medicaid FFS does not reimburse for MCTs, resulting in a reimbursement gap for the minority of Medicaid clients enrolled in FFS Medicaid.

Encouraging providers to bill for services is also challenging. Despite limited budgets that MCT providers generally operate under, some providers decline to bill for a variety of reasons, including believing their funding is sufficient or the billing system is too complex. New York’s OMH offers technical assistance to providers in how to successfully bill and encourages billing MCOs, when possible, because the additional funding stream could be used to expand services, such as operating around the clock or hiring additional staff. The relationship between OMH and providers was characterized as bi-directional, as OMH supports providers through technical assistance, and provider organizations send OMH feedback that shapes licensing requirements and billing rates. OMH currently is working on a SPA to expand MCT coverage from Medicaid managed care beneficiaries to all Medicaid enrollees.

## 4.2 Montana's Coverage of Medication for Opioid Use Disorder (MOUD)

In Montana, MOUD services (provider visits, medication prescription, lab testing, medication distribution, and integrated behavioral health management) can be reimbursed through a bundled payment. Counseling services are billed separately, a notable exclusion from the bundled payment. To qualify for reimbursement through the weekly Medicaid MOUD bundled payment, the client must have had a visit with a medical provider in the past month. Medicaid MCOs reimburse at separate bundled rates for OTPs and office-based opioid treatment (OBOT), and two types of MOUD service bundles are reimbursable: MOUD intake (billed during the first week of treatment) and MOUD established care (billed after the first week of treatment).

When MOUD was first introduced in Montana, it was funded by SAMHSA’s State Opioid Response and State Targeted Response grants. MOUD then transitioned to being reimbursed through Medicaid FFS, and in July 2020, Medicaid bundled rates became available. To create the bundled rates, state Medicaid administrators examined the FFS codes that were being billed, spoke to subject matter experts about what is clinically appropriate for treatment of OUD, consulted with Montana providers about team-based workflow and associated costs, and reviewed commercial insurer’s rates for MOUD services. Administrative interviewees reported that the bundled rates were developed because of concerns over billing inconsistencies across MOUD providers. Administrators and providers emphasized that, compared to FFS, the bundled rate de-incentivized overutilization of profitable but unnecessary and invasive services such as urinalysis. Bundled payments gave providers the flexibility to develop a protocol for care and testing that centered around patient needs and clinical appropriateness. Montana plans to further develop MOUD bundled rates: the state has submitted a SPA proposing to establish a readmission rate, to augment the existing two bundled rates for intake and established care. The SPA also adds care coordination to the list of services that trigger bundled payments.

According to the providers, bundled rates simplified their billing process. Providers reported that billing MOUD under FFS could be burdensome because clients often require frequent encounters, with variable clinical needs, and under FFS, each service within an encounter is billed individually. Providers also emphasized how critical bundled rates were to maintaining and expanding their service provision, citing the more predictable nature of the bundled payment and the consistency of payment over time, compared to FFS billing. The bundled rates also directly support team-based care; the consistent and predictable payment supported the hiring of peer support specialists, intra-team communication, and client outreach, services that are not reimbursable under FFS. Furthermore, the bundled rates have given state administrators clearer data about how frequently MOUD is being provided and by whom. While Montana’s FFS billing system does not distinguish claims for MOUD from claims for other treatment for clients with OUD, state administrators can be certain that providers who receive bundled payments are providing MOUD. The ability to identify MOUD providers through claims data supports the state Medicaid program’s efforts to identify geographic areas of need as well as to target providers for technical assistance on bundled payment through Medicaid.

At the time of our interviews, only four programs in Montana were billing for MOUD at the bundled rate; most providers still bill Medicaid FFS for MOUD. Limited provider uptake of the bundled billing approach was attributed in part due to a lack of outreach and education directed at providers on the new billing mechanism. Our administrative interviewees theorized that early providers of MOUD may not be aware of Medicaid bundled reimbursement and that providers may be hesitant to move away from the FFS billing approach that they are familiar with. Administrative interviewees also reported that more outreach and technical assistance by Medicaid is needed, especially toward smaller OBOTs, to increase awareness of the bundled payment. Digital infrastructure also presents a challenge to uptake of the reimbursement mechanism. Many behavioral health providers in Montana do not have EHRs or have only recently developed them, an issue that is compounded by limited broadband access in parts of the state. Lack of digital infrastructure presents a barrier to team-based care because it can facilitate service documentation and billing.

## 4.3 Aware In-Home Substance Use Disorder Recovery

Aware is a service delivery model of SUD treatment that brings residential-style treatment into the home. Aware was founded on the principle that the most effective SUD care takes place in the home and requires more than a 3-month tenure; the model considers 12 months a more reasonable timeline for stabilization than more common short-term stabilization services. After a pilot study demonstrated Aware’s effectiveness,^44^ Anthem collaborated with Aware to develop a bundled rate for holistic, in-home SUD treatment. The bundled rates are intended to de-incentivize unnecessary but profitable services, like urinalysis, and to provide the flexibility to support the high-touch nature of SUD services. Bundled service billing also simplifies the payment process for commercial patients because there is only one co-pay per month, limiting patient cost-sharing for high-touch care. The model has expanded to multiple commercial payers since inception.

Complications remain in the billing process: codes for this service vary by insurance plan, although some codes are similar across payers. Payers are working toward greater uniformity in coding. The interviewee also emphasized the importance of EHR in tracking patient encounters and facilitating billing within a treatment model as intensive and complex as Aware.

Providing this model of care and reimbursement faces additional challenges related to staffing and program expansion. In-home addiction treatment is labor-intensive, and given current shortages in the behavioral health labor market, particularly during the COVID-19 Public Health Emergency, consistent staffing remains a barrier for this service delivery model. Participating commercial payers also vary in the types of paraprofessionals they employ. Certified Recovery Advisors, a key feature of the model, were reported as being increasingly accepted by commercial insurers, but other paraprofessionals that were integral to Aware, such as Family Education Facilitators, have not yet experienced this rise in acceptance. Aware is advocating for a nationally recognized billing code for their service bundle, citing the advantages to expanding across commercial payers and states under a recognized billing code.

In its expansion to new states and payers, Aware representatives emphasized that preexisting contracts with commercial payers in one state facilitated the development of contracts with those payers in other states. However, program expansion is a labor-intensive process, requiring legal, compliance, project management, and accounting staff. Aware is also weighing expansion to serve Medicaid enrollees. However, expansion under Medicaid brings challenges: both CMS reporting and the treatment model itself are labor-intensive and thus costly, and Medicaid’s fee schedules are generally less than those of commercial payers.

## 4.4 New York Health Home Plus (HH+) Program

HH+ is a component of New York’s state Health Home program, which is focused on Medicaid enrollees living with SMI. Health Home is a treatment modality that uses integrated care, coordinated care, and transitional care to holistically address physical health and social determinants of health. HH+ incorporates Health Home services, but at a higher level of intensity (e.g., more face-to-face contacts, low caseload sizes), specifically for patients who have SMI and who meet other qualifications (e.g., court order to undergo treatment, recent discharge from a state psychiatric center, recent release from prison). New York has 200 OMH-designated Care Management Agencies (CMAs) that provide HH+ services to about 25,000 individuals.

HH+ developed from New York’s existing care management system, TCM. Whereas TCM focused solely on mental health, HH+ uses an integrated care model to address both behavioral and physical health. The PMPM rate is set to factor in the high-intensity integrated care needed by the HH+ population; thus, rates for HH+ are higher than rates for Health Home. New York state selected PMPM as the reimbursement mechanism for HH+ to allow providers the flexibility to develop innovative service delivery approaches.

Both provider and administrative interviewees noted that New York’s HH+ system’s robust HIT system facilitated team-based care and reimbursement. Like New York’s MCTs, HH+ has access to PSYCKES for care coordination. The provider interviewee reported high administrative and information technology knowledge requirements, and that the requisite staff training was time-intensive, but that digitizing the CMA’s record-keeping allowed for more rapid communication between team members and more comprehensive care for patients.

The formalized communication between OMH and HH+ providers was linked to the iterative development of the HH+ rate over time, as well as to the subpopulations that were gradually added to the service definition. In keeping with the iterative development process, the administrative interviewees indicated their interest in building on the reimbursement mechanism to include pay-for-performance elements.

## 4.5 Pennsylvania Centers of Excellence (COEs)

In Pennsylvania’s COEs, care managers integrate outpatient OUD treatment with physical health treatment. To reimburse COEs, Pennsylvania’s Office of Mental Health and Substance Abuse Services (OMHSAS) passes funding to MCOs, which must then direct the funds to a specified list of COE providers at a current rate of $277.22 PMPM. COE services are covered for Medicaid MCO beneficiaries. Before transitioning to PMPM via MCOs, Pennsylvania COEs were originally funded by a state demonstration grant. This start-up grant funding allowed COEs time and financial freedom to develop systems to deliver the most appropriate care and to recruit and train qualified staff. The COEs then transitioned to MCO reimbursement as a more sustainable funding source, compared to time-limited grant funding. OMHSAS used grant expenditure data when calculating the PMPM rates.

Administrator interviewees emphasized the importance of technical assistance for providers in gaining support among MCOs for the reimbursement method. State administrators and their university partners provided individualized technical assistance to COEs and open channels for MCO feedback, which encouraged MCOs’ buy-in. Both administrator and provider interviews indicated that incentivizing providers to retain patients in care is a key strength of the PMPM mechanism. Although both administrator and provider interviewees agreed that the PMPM rate of $277.22 generally did not cover the cost of the high-intensity care needed in the first month of treatment, program administrators emphasized that they intended the rate to “pay off” over the course of 6–12 months of treatment. An administrative interviewee highlighted that the bundled payment allowed COEs additional flexibility in how best to address their clients’ needs. For example, some COEs have taken on the role of whole-person care, by intervening on social determinants of health and partnering with community-based housing, transportation, childcare, or food security organizations. Interviewees also noted adaptations in the bundled rate: two MCOs have increased the PMPM to include physical and behavioral health care in the same bundled rate.

Concerns surrounding the PMPM mechanism included its potential to incentivize client volume and preferential retention of low complexity patients, who garner the same PMPM as high complexity patients. Interviewees reported that some providers perceive the reimbursement rate as failing to cover the full cost of care during the early months of treatment. For the next development phase of the COE reimbursement mechanism, interviewees expressed interest in tying reimbursement to key performance measures, and in tiered reimbursement that is more aligned with treatment stage and intensity.

## 4.6 Findings Across Case Studies

We focused on a range of programs that are successfully reimbursing for team-based behavioral health care. Consequently, case study findings are responsive to this report’s second research question focusing on barriers and facilitators to implementation and maintenance of reimbursement practices that support team-based behavioral health care. The design of the case studies, in which four of the five case studies included both administrative and provider interviews, allowed us to identify and triangulate barriers and facilitators of team-based care reimbursement, on both the administrative and the provider sides. Several key themes emerged in multiple case studies, ranging from the importance of grant funding in developing novel reimbursement mechanisms, iterative development of reimbursement mechanisms, and collaborative relationships between administration and providers.

State or federal grant funds were instrumental in developing and adopting novel reimbursement mechanisms or rates. Although interviewees consistently emphasized the importance of sustainable reimbursement mechanisms, most interviewees reported depending on grant funding playing a temporary but key role in the development and adoption of their current reimbursement mechanism. Interviewees used early-stage funding to support collaboration with local universities to design evidence-based bundles of services, develop technical assistance partnerships with universities, solicit current service utilization and associated costs from providers, and build relationships with providers for iterative feedback on the mechanism. Grants incentivized providers to appropriately implement the evidence-based services, ensuring the processes and staff were ready for the bundled payment rates. Case studies focused on Pennsylvania’s COE and Montana’s MOUD bundled rate are both striking examples of state and federal grant funding, respectively, playing a key role in the development and implementation of novel reimbursement mechanisms. In addition, in the case of New York’s MCTs, provider interviewees emphasized the importance of combining funding streams from reimbursement and state or local funds, or “braided funding,” to bridge the gaps between FFS and the actual cost of care.

Iterative communication and feedback between administrators and providers were key facilitators of both the reimbursement mechanism development process and successful implementation and maintenance. Multiple interviewees reported that close relationships between the administrators and providers led to more clinically appropriate reimbursement rates, a more responsive refinement cycle of the reimbursement mechanism, and better-informed providers.

On the administrative side, several programs emphasized the importance of technical assistance in helping providers successfully transition to new billing requirements. In the Pennsylvania COEs, state funding allowed the COEs to collaborate with local universities in their technical assistance efforts, which allowed providers to have their reimbursement questions answered rapidly and allowed administrative contacts to reinforce the effectiveness of the bundled rate through data summaries back to providers. Interviews also captured the value of the technical assistance relationship to providers as a conduit for incorporating provider feedback into the development and evolution of bundled case rates. Interviewees in Montana, Pennsylvania’s COE, and New York’s HH+ program reported that they considered a combination of documented practice costs and qualitative descriptions of workflow in the development of their reimbursement mechanisms. In the case study on Montana’s OUD bundled rate, providers emphasized the personal and informal connection to the state administrators, given the size of the state, whereas the case study on New York’s HH+ program emphasized a more formal relationship between providers and state administrators. Over the years, HH+ has also expanded the populations eligible for HH+ based on stakeholder and provider feedback. Stakeholder and provider feedback also guided the development of the HH+ rate, determined by caseload, staffing qualifications, and contact requirements.

Models serving clients covered by a single type of payer were more successful in covering the costs of care. Both Aware and New York’s HH+ program are linked to their payer type: Aware serves beneficiaries enrolled in commercial health plans, and the HH+ program serves Medicaid enrollees. Within models that were designed for reimbursement by a single payer type, interviewees reported advantages of specialization: Aware and HH+ interviews referenced efficiencies gained by focusing on a specific population in terms of providing tailored care. In the case of HH+, interviewees emphasized that reimbursement rates had been iteratively tailored to complex and high-need populations, often based on provider feedback. Aware representatives, in turn, focused on the advantages conferred by the ability to leverage connections with a commercial payer across multiple states in which that payer was active. By contrast, in the case study of New York’s mobile crisis program, characterized by serving clients regardless of insurance status, the range in client payer mix was cited as a barrier to consistent FFS billing, as reimbursement practices for mobile crisis vary widely across payers.

Across the case studies, we also identified several key barriers to successful and sustainable reimbursement of team-based behavioral care. First, provider perceptions of underfunding remained an issue across mechanisms. Second, in case studies in which services were provided to a broad client mix, regardless of payer, interviewees noted that the primary reimbursement mechanism (generally Medicaid) was effectively subsidizing the care received by clients enrolled in other payers. In the case of the Pennsylvania COEs and Montana’s MOUD treatment, both reimbursement mechanisms were tied to the Medicaid beneficiaries being served, despite providers serving a broader mix of beneficiaries. Third, geographic challenges remain for reimbursement where outreach and transportation costs are more substantial due to rurality (e.g., Montana), though programs such as New York’s HH+ mitigates geographic barriers through distinct reimbursement rates for different regions. Finally, where states invested in digital infrastructure, we saw those investments support both successful team-based care and the reimbursement process. By contrast, where digital infrastructure was absent or when providers referred to times preceding its implementation, the absence highlighted its importance in: (1) intra-team communication through electronic visit notes and visit follow-up reminders; (2) the identification of both patients and providers; and (3) communication between provider teams and larger organizations, such as MCOs, state Medicaid programs, and health homes.