# 3. Findings: Environmental Scan and Case Studies

## 3.1 Team-Based Models of Care and Reimbursement Mechanisms

We identified 11 models of team-based care, based either on novelty or widespread implementation. For a summary description of each model, see Table 3-1. Models had varying degrees of homogeneity in implementation. Some follow a well-defined structure of team members and service composition while others share a patient population and general team and treatment approach. This section also covers each model’s most common reimbursement mechanism, funding sources, the payer or payers that reimburse for the model’s services, and common funding gaps. A summary of the primary payer and common reimbursement mechanism for each model can be found in Table 3-2.

Table 3-1 Team-Based BH Model Descriptions

Model | Model description
Coordinated Specialty Care (CSC) | Recovery-oriented treatment program for people with first episode of psychosis.
Mobile Crisis Teams (MCTs) | Community-based service in which teams travel to provide services to an individual in crisis.
Pediatric-Child Psychiatry Teleconsult | Pediatric MH specialists provide teleconsultation, training, and care coordination to pediatric PCPs.
Sustained Addiction Recovery | Sustained Addiction Recovery models provide comprehensive care specific to addiction treatment with an emphasis on long-term recovery and relapse prevention.
Emergency Department-based Treatment and Support | Includes programs that connect individuals presenting with SUD at EDs with SUD treatment services, often including trained peer advocates who offer recovery supports.
Opioid Treatment Programs (OTPs) | Includes programs that provide outpatient treatment for patients with OUD. This model emphasizes care that is primarily focused on OUD treatment for both Medicare and Medicaid beneficiaries.
Opioid Health Home(OHH) | These OUD treatment models provide comprehensive and integrated outpatient treatment services, including care management and coordination, and focus on the Medicaid population.
Behavioral Health Homes (BHH) | These comprehensive care teams serve Medicaid beneficiaries suffering from SMI. BHHs integrate community supports, often including social workers and peer specialists.
Psychiatric Collaborative Care Model (CoCM) | The CoCM is characterized by a treatment team that includes a PCP, a psychiatric consultant, and a BH care manager. Originally designed for the Medicare population, state Medicaid programs have the option to include CoCMs billing codes, and the codes have been adopted and adapted by some commercial plans.
Assertive Community Treatment (ACT) | ACT provides multidisciplinary treatment to support those with SMIs. ACT team members help patients with medication, therapy, physical health, social support, employment, or housing. ACT has several client populations, focusing on individuals who are transitioning between care settings (e.g., acute inpatient to community care).
Certified Community Behavioral Health Clinic (CCBHC) | CCBHCs provide 9 essential services and care coordination, including 24-hour MCTs, screening and assessment, patient-centered treatment, outpatient MH and substance use services, outpatient primary care screening, TCM, psychiatric rehabilitation services, peer supports, and community-based MH care.

### Coordinated Specialty Care (CSC) Model

CSC models focus on treating mental health conditions in young adult and adult populations suffering first episode of psychosis.^11^ CSC models are recovery-oriented treatment programs implemented by a multidisciplinary team that generally includes a Master’s level clinician as team leader,^12^ responsible for team coordination and non-billable interactions (e.g., team meetings), a psychiatrist, and an educational or vocational specialist. Teams also often include a licensed clinical social worker or certified alcohol and drug counselor to lead group or individual psychotherapy, and a nurse or peer responsible for case management.^13^ In addition to services provided directly to clients, CSC programs prioritize community outreach because of the model’s emphasis on identifying individuals in early stages of psychosis.

These models commonly rely on fee-for-service (FFS) reimbursement through Medicaid and private insurance. However, even for covered services such as medication management and individual therapy, there are indications that the standard billing rates may not align with the intensity of services provided.^14^ In addition, specific CSC services, such as supported employment and education services or outreach activities, are difficult to bill for under Medicaid or commercial FFS systems, leading to a patchwork approach to financing. Providers rely on grant funding, including SAMHSA’s Community Mental Health Services Block Grant program, and state funds to fill the gaps.^14^ Some CSC programs draw on alternative reimbursement mechanisms to cover the costs of otherwise non-covered services, and our scan yielded examples of providers being paid by a cost-based bundled monthly payment from Medicaid managed care organizations (MCOs).^11^ In these examples, the monthly rate was determined by actuarial studies of bundled CSC services, though the bundled payment often excluded supported education and employment services. Lack of coverage for specific services, variable coverage across payers, and reliance on other funding sources remain key issues.

### Mobile Crisis Team (MCT)

MCTs provide emergency behavioral health services to individuals in crisis.^15^ These teams generally include both licensed or credentialed behavioral health professionals, who are capable of assessing the individual in crisis, and a paraprofessional, often a peer support specialist or psychiatric technician. Although MCTs are often able to draw on Medicaid reimbursement, state Medicaid programs vary widely in coverage and rates,^16^ and the majority of MCT programs remain reliant on state and local funds. Most MCTs bill Medicaid FFS, though commercial coverage exists in some states as well. The level of funding for the teams varies heavily by state and county and can also vary year-to-year, depending on local budgets, leaving providers to navigate an inconsistent funding landscape. The development and sustainable financing of MCTs is a national priority and under the American Rescue Plan, additional federal funds are allocated to states interested in developing their mobile crisis intervention services. States are able to apply for this option under Medicaid and to develop crisis services tailored to their state’s needs.^17^

### Pediatrician-Child Psychiatry Teleconsult Model

This model gives primary care providers (PCPs) access to multidisciplinary teams that can provide pediatric psychiatry consultations.^18^ Psychiatric teleconsultation is designed to increase provider capacity by connecting PCPs with specialty providers and other psychiatric resources. This model is distinct from other models discussed in that it describes a system in which providers consult with other providers, instead of providing services directly to patients. This model provides PCPs with access to teams that can include a behavioral health specialist (such as a child or adolescent psychiatrist), a care coordinator, and a referral specialist. These teleconsult services frequently rely on grant funding over traditional reimbursement mechanisms, though there are examples of teleconsultation programs being paid through Medicaid MCOs.^19^ Grants and state funds directly pay for the psychiatrist (or other specialty providers), who provide on-call consultations to PCPs who are providing direct services to their patients. Although this model is reliant on grant funding, the direct payments to providers ensure that consultations and referral support are consistently compensated and available as-needed. As with other models that rely on grant funding, sustainable financing is a key issue for psychiatric teleconsultation.

### Sustained Addiction Recovery

Sustained addiction recovery encompasses two distinct models developed to treat SUD in adults. The two models are Addiction Recovery Medical Home-Alternative Payment Model (ARMH-APM)^20^ and Aware Recovery Care.^21^ ARMH-APM is an alternative payment model designed to provide patients with a long-term, comprehensive, and integrated pathway to addiction treatment and recovery over a 5-year program encompassing three treatment phases. The first phase focuses on pre-recovery and stabilization efforts across the variety of initial settings for patients seeking treatment for SUD (i.e., general emergency or acute care settings). The second phase involves a closely managed course of treatment for up to 12 months in an institutional setting. The final phase lasts up to 4 years, following the patient in a variety of community-based non-institutional settings. Across the phases, ARMH-APM includes a recovery coach, care coordinator, PCP, and an addiction or behavioral health specialist.

Aware Recovery Care is characterized by its in-home SUD treatment approach, for individuals with commercial insurance coverage. The program is designed to last 52 weeks and includes psychotherapy and psychoeducation components, both for the individual and for the family. In addition to psychotherapy, the Aware treatment approach includes medication-assisted treatment (MAT), occupational therapy, life skills coaching, and legal assistance. Some of the regional Aware programs offer in-home withdrawal management in addition to SUD treatment and related therapies. Aware teams include a PCP, individual therapist, family therapist, and a psychiatrist.

Aware is offered in eight states and reimbursed as a bundled rate by commercial payers, while ARMH-APM has been implemented within Medicaid MCOs. ARMH-APM applies a specific reimbursement strategy to each phase of recovery, beginning with FFS for pre-recovery and stabilization services, and bundled payments tailored to the institutional and subsequently non-institutional settings in the last two phases. These bundled payments apply across care settings as part an integrated and centralized design to combine acute, outpatient, and behavioral health providers as part of a continuous treatment process. While ARMH-APM necessarily takes place across many treatment settings, Aware Recovery Care is home-based, and it includes family members in the therapeutic process. The Aware team splits a monthly bundled payment for at-home addiction recovery treatment.

### Emergency Department-Based Treatment and Support Models

These models connect adults presenting with SUD in emergency departments (EDs) with SUD treatment services and peer recovery supports.^22^ Emergency department care teams generally consist of nurses, physicians, pharmacists, social workers/case managers, and peer support specialists.^23^ Peer support specialists assess and engage patients and provide education on overdose prevention, while the medical team ensures medical stability, diagnosis, and treatment initiation. Peer coaches also play a crucial role in facilitating referrals to community resources and treatment, and in some cases facilitate the transfer of electronic health records (EHRs) to community treatment programs. Although Medicaid covers peer services, grant funding and local funds are often necessary to compensate for coverage gaps for team-based communications and care coordination activities. These models face additional reimbursement challenges because, outside of Medicaid, peer support services are generally not covered by commercial insurance or Medicare.

### Opioid Treatment Program (OTP)

OTPs are certified and accredited facilities that can dispense medication for OUD (MOUD), including methadone, in addition to providing other support services such as individual counseling and group therapy. In several states, OTPs play a pivotal role in larger opioid use disorder (OUD) care teams, through the “hub and spoke” model^24–26^ and other collaborative care models.^27^ Originally developed in Vermont, the OTP forms the “hub” of specialized OUD care for patients with more severe care needs, and primary care practices function as “spokes,” offering OUD treatment for stabilized patients. OUD treatment by OTPs is reimbursable through Medicare as a bundled payment^28^ and the SUPPORT Act recently mandated that all state Medicaid programs cover OTP services.^29^

### Opioid Health Home (OHH)

OHHs are paid for by Medicaid programs and provide more holistic care compared to OTPs.^30^ OHH teams offer an extensive set of services organized by comprehensive care management of services, medications, and tests. Care coordination includes assistance and support related to social determinants of health (legal, housing, and employment assistance). Specific services are provided to promote a healthy lifestyle including nutritional counseling, exercise plans, relapse prevention plans, and supports for managing chronic pain. OHHs also offer comprehensive assessment and transitional care, as well as referral to community, social support, and recovery services. OHH staffing is uniform across programs, generally including a Health Home director, PCP, case manager, registered nurse, certified peer recovery coach, community health worker, and a Health Home coordinator. OHHs are generally reimbursed on a per member per month (PMPM) basis for home health services, while payments for medications are generally handled on a FFS basis.^31^

### Behavioral Health Home (BHH)

BHHs serve Medicaid beneficiaries with SMI and require a Medicaid state plan amendment (SPA) to implement. As is standard with health homes, BHH offers comprehensive care management, as well as care coordination for physical and behavioral health treatments, and community-based long-term services and supports. BHHs also offer health promotion and individual and family support, comprehensive transitional care and referral to community and social support services, including housing. BHH staff generally include physicians, nurse care coordinators, social workers, and other behavioral health professionals such as counselors. The reimbursement scheme for BHHs is dependent on the state Medicaid system. States are free to develop innovative reimbursement mechanisms, but most reimburse using PMPM payments.^32^

### Psychiatric Collaborative Care Model (CoCM)

The psychiatric CoCM (henceforth, CoCM) provides integrated behavioral health care for individuals with less complex conditions such as depression or anxiety. The CoCM is delivered by a team of PCPs, psychiatrists, and behavioral health care managers. The model offers an initial behavioral health assessment followed by monthly meetings with a behavioral health care manager and consultations and treatment from a psychiatric consultant qualified to prescribe a full range of medications. Monthly rates covering these services were first adopted by Medicare in 2017.^33^ The time-based charge code for CoCM allows for a wider range of services and coordination between providers than is typical in FFS arrangements. Medicare’s CoCM reimbursement model has been adopted and adapted by some state Medicaid programs and by some commercial payers. However, there are indications that commercial payers have lagged behind Medicare in the adoption of CoCM payment approaches.^34^

### Assertive Community Treatment (ACT)

The ACT model provides care to patients with SMI who have recently been transferred out of inpatient settings. They provide a low client-to-staff ratio, 24-hour staff availability, and community-based and directly provided services. ACT interventions might include psychopharmacologic treatments such as atypical antidepressant or antipsychotic medications, mobile crisis intervention, or group therapy.^35^ In addition, ACT offers behavioral training for activities of daily living, support for resuming education and employment, and other support services including education for families as well as financial, housing, and transportation support. ACT teams include a psychiatrist, supervisor, care managers, peer support specialists and nurses.^35^ ACT models are funded by state Medicaid agencies with additional support from state funds. Services for Medicaid FFS beneficiaries are billed using a unified billing code. However, there are limitations to billing for ACT services: the vocational and education services in the ACT models are often not covered by state Medicaid programs, and Medicare does not currently reimburse for ACT services.^36^

### Certified Community Behavioral Health Clinic (CCBHC)

CCBHCs provide at least nine essential services along with care coordination, including 24-hour MCTs, screening and assessment, patient-centered treatment, outpatient mental health and substance use services, outpatient primary care screening, targeted case management (TCM), psychiatric rehabilitation services, peer supports, and community-based mental health care for veterans.^37^ There is a general requirement for teams to include a psychiatrist as a medical director and a chief executive officer or project director. Additional team member requirements vary by state but generally include a medically trained behavioral health provider able to prescribe and manage medication, credentialed substance use specialists, and individuals with trauma expertise able to promote recovery of children with serious emotional disturbance, adults with SMI, and those with SUD.

CCBHCs are Medicaid-funded models that began as demonstrations but have since expanded. The original demonstration CCBHCs have nine specified services that are core to the model for which the teams are reimbursed with a prospectively determined bundled rate through its Prospective Payment System (PPS) for either a daily visit, or a monthly rate for individuals who have received services in the month (depending on the state). The PPS is paid even if the service provided is not normally covered by the state’s Medicaid program. While the CCBHCs are expected to serve an all-payer patient-mix, they receive the PPS rate only for Medicaid beneficiaries. Outside of the demonstration CCBHCs, the “expansion” CCBHCs, by contrast, receive reimbursement using their regular billing mechanisms. Expansion CCBHCs can charge all payers for services and must do so before accessing reserve grant funds that pay for non-reimbursable services and for services provided to underinsured or uninsured individuals.

## 3.2 Common Reimbursement Mechanisms

Team-based models rely on a variety of reimbursement mechanisms, some including multiple mechanisms within the same model. Traditional FFS is the most common form of reimbursement, where providers bill for discrete services priced on a fee schedule based on labor and material inputs. Traditional FFS has several limitations, including an incentive for overtreatment and the inability to reimburse certain team members and activities that are not associated with a specific billing code. In addition to traditional FFS, some models were able to use enhanced FFS billing, where the Current Procedural Terminology (CPT) code rate is set to account for team-based activities. An example of this is the billing code for the CoCM model. Enhanced FFS arrangements have minimal barriers to entry for participating providers and payers, because of providers’ familiarity and widespread use of the codes. In addition to adjusting the rates for existing codes, some team-based models leverage novel billing codes to bill for services not currently covered under an existing CPT.

Alternative reimbursement mechanisms, such as bundled payments^38^ and PMPM payments,^39^ are in use in some team-based care models. Bundled payments are a payment to providers based on an expected bundle of services; the bundled rate may be set based on an average FFS cost for treating a given diagnosis, or, more comprehensively, based on estimated cost of providing a bundle of team-based services. These bundled payments may include incentive payments for achieving savings or meeting goals based on quality measures. Often set at as weekly or monthly intervals, bundled payments allow for a more flexible suite of services, where services provided are driven by individual patient need, and are less prone to incentivizing overuse of high-cost, unnecessary services.

PMPM payment is another alternative to FFS. PMPM budgets a set payment for care for a given beneficiary, often requiring at least one service to trigger the monthly payment. PMPM payments also address FFS issues related to overtreatment and coverage gaps. It does this by capping the reimbursement amount, incentivizing necessary care while still allowing for more treatment variety and flexibility because reimbursement is not tied to specific CPT codes. For a summary of the reimbursement models used in each model and the primary payer using that mechanism, see Table 3-2.

The reimbursement mechanisms described above each address some of the common issues in sustainably funding team-based behavioral health care. As noted above, FFS mechanisms can present barriers to billing for some team-based services and team members, but also for billing for indirect care such as team meetings, care coordination, and community or patient outreach, all key components of many team-based models. Enhanced FFS partly addresses the issue of indirect care by setting higher reimbursement rates, to reflect indirect care costs, while bundled payments and PMPM are better suited to ensure that the whole team is covered and providing greater flexibility for the range of services that providers can offer.

Another common hurdle for team-based models is the lack of reimbursement for time spent on-call. Models such as MCTs are designed to reach patients at the location where the crisis is occurring and are designed to respond quickly. However, neither travel time nor time spent on-call can be reimbursed under FFS. MCTs compensate for these reimbursement gaps with local and state grant funding, or when those financing approaches fall short, by increasing response times or reducing hours of operations. Models that face similar barriers include psychiatric teleconsultation and emergency department-based treatment and peer support.

Models that serve a patient-mix distributed across multiple payers contend with the challenge of a fragmented payer environment, in which not all payers cover the same services, and, when they do, often do not reimburse at the same rates. Because payers are not required to cover identical services, “payer-agnostic” models, in other words, models in which all patients are treated using a team-based approach, regardless of payer, will be reimbursed for team activities only by a subset of patients.

Table 3-2 Primary Payer and Common Reimbursement Mechanism, by Model

Model | Primary Payer | Common Reimbursement Mechanism
Coordinated Specialty Care (CSC) | Medicaid | FFS for billable individual services in the model. Grant funding is used to cover providers and services not reimbursable by payer, or those services are omitted from the model.
Mobile Crisis Team (MCT) | Medicaid | Although state and local funds are the most common source of financing, Medicaid FFS billing is the most common reimbursement mechanism. Some commercial payers cover MCTs.
Pediatric-Child Psychiatry Teleconsult | Direct Funds | Providers receive direct payments from state governments for participating in grant-funded services rather than through a reimbursement-based payment. Some examples of reimbursement through Medicaid MCOs.
Sustained Addiction Recovery | Commercial | Sustained addiction recovery models rely on bundled payments, In the case of ARMH, the program combines a brief FFS during the stabilization phase, followed by tiered bundled payments, in addition to incentivizing performance on recovery-linked quality measures. A second model, Aware Recovery Care, reimburses through monthly, bundled payments.
Emergency Department-based Treatment and Support | Medicaid | Medicaid FFS billing. Some states have added enhanced FFS to cover long-term services provided by peer support specialists while others cover peers with grant funding.
Opioid Treatment Program (OTP) | Medicaid, Medicare | Weekly bundled payment under Medicare and, more recently, a daily bundled payment under Medicaid.
Opioid Health Home(OHH) | Medicaid | Medicaid PMPM payments for Health Home services, while medication is generally billed FFS.^31^
Behavioral Health Home (BHH) | Medicaid | Medicaid PMPM payments for Health Home services, often tiered by disease severity.^32^
Collaborative Care Model (CoCM) | Medicare, commercial | Time-based enhanced FFS billing codes that allow for reimbursement of patient care performed outside of face-to-face encounters, including consultation services and patient outreach.^40^
Assertive Community Treatment (ACT) | Medicaid | Enhanced FFS where the FFS billing code is a unified billing code covering a range of services by the ACT team.
Certified community Behavioral Health Clinic (CCBHC) | Medicaid | Demonstration CCBHCs: a bundled rate for Medicaid enrollees for any of 9 covered services.^41^; Expansion CCBHCs: FFS billing, where FFS must be applied before grant funding can be used.

## 3.3 Examples of Models Using Various Reimbursement Mechanisms

### More Inclusive or Flexible FFS Billing Codes

Several models and states use adjusted or enhanced FFS billing codes. For well-established models, such as ACT, most state Medicaid programs have adopted a billing code specific to the ACT services (H0040)--this code is a per diem charge covering all potential ACT services, rather than a single discrete service. By comparison, reimbursement for CSC generally occurs service-by-service, leaving components of the model such as outreach and supported employment as unreimbursed, depending on state Medicaid coverage.^11^ Although CSC programs generally bill using traditional FFS billing, there are several notable exceptions, such as Philadelphia and Delaware counties in Pennsylvania using the T1024 billing code (“evaluation and treatment by an integrated specialty team”), reimbursing for CSC as a bundled payment. Similarly, emergency department-based peer support models are often able to bill for peer support specialists using FFS billing, and some states have broadened those billing codes to cover more sustained contact. For example, New Jersey’s peer support services billing code (H0038 HF X3) corresponds to 8 weeks of Recovery Specialists and Patient Navigators services, easing the coding burden and guiding clinical practice towards sustained follow-up and support through the stabilization phase.

There are several adjustments to Medicare billing codes that can support team-based care. Beginning in calendar year 2018, Medicare began making payments for CoCM, using CPT codes 99492, 99493, and 99494. These CoCM billing codes are intended to enhance primary care through the addition of behavioral health care managers and psychiatric consultation. However, adoption of the CoCM within Medicare lags behind other novel care management codes, and fewer than 0.1% of individuals with behavioral health conditions received services through the novel code type in 2017 and 2018.^42^ In addition, despite rollout under Medicare, state Medicaid authorities may elect not to implement the novel billing codes. As of August 2020, only 17 states were reimbursing for CoCM codes in their state Medicaid programs. Further, state-specific differences in implementation allow for state Medicaid programs to exclude beneficiaries based on diagnoses, set prior authorization requirements, as well as specify team credentials and set billing provider limitations.^33^

### Alternatives to FFS

The environmental scan identified several instances of especially innovative departures from traditional FFS. ARMH is a particularly salient example of a model that offers: (1) a departure from FFS billing; and (2) flexibility within the model to draw on different reimbursement mechanisms and rates depending on recovery stage (stabilization, active treatment, and recovery management).^20^ Similarly, in a move toward more flexible reimbursement, Pennsylvania’s ACT program incorporates pay-for-performance components within a Medicaid MCO, which can incentivize team-based care. Finally, the PPS reimbursement mechanism used by the demonstration CCBHCs allows for more flexible provision of team-based services. The flexibility provided by PPS supports team-based behavioral health care within the CCBHC, and serves as a vehicle for other team-based care models such as ACT, CSC, and MCTs.^37^