# 2. Methods

To identify team-based care models and associated reimbursement strategies, we conducted a scan of peer-reviewed articles, gray literature, industry reports, presentations, and website content. We used key search terms in general Internet searches (Google) as well as in searches of scholarly literature (Google Scholar). Detailed search terms and logic can be found in Appendix A. In addition to these searches, we conducted scans within government and other stakeholder websites that are relevant to team-based care (e.g., Centers for Medicare & Medicaid Services [CMS] and Substance Abuse and Mental Health Services Administration [SAMHSA]).

We supplemented our scan with information from interviews with subject matter experts in behavioral health care delivery models and reimbursement mechanisms. We conducted six interviews with nine stakeholders who represented commercial and public sector mental health and substance use service delivery systems, as well as experts knowledgeable in the inclusion and reimbursement of peer support in team-based care. Three interviews focused on national policy related to health care financing, two interviews focused on team-based care within commercial plans, and one interview focused on peer support specialists. Interviews were approximately 60 minutes long and were conducted over Zoom. We recorded and used Temi to transcribe each interview. We then reviewed the transcripts for key takeaways and common themes. Next, we compared the interview findings to the environmental scan results to identify similar and contrasting trends.

Based on the environmental scan, we identified 11 types of team-based care models. We developed a catalog to compare reimbursement mechanisms and strategies within and across models. The catalog includes salient information that was publicly available about the payer, funding sources, and reimbursement mechanisms (i.e., how providers are paid). We included billing codes and rates when possible, and we provided notable information about provider teams, common or required components of service depending on the model, billing or service restrictions, characteristics of the model, and whether peers were involved in service provision. Within models that were widely implemented, we documented variation across states. For each model, we compiled information on treatment approach, population served, and common composition of provider teams by state. Where we noted sufficient consistency in treatment approach and patient population across states, we summarized those characteristics at the model level instead of breaking them out by state. In all models, we noted variation in specific services covered, which often is due to state-level variation in implementation and coverage.

Based on the environmental scan and reimbursement catalog, we selected five models of team-based behavioral health care with innovative provider reimbursement approaches to explore in detail as case studies. Within each case study, we recruited interviewees by contacting health department or other program administrative staff as well as providers for each case study organization. We identified administrative contacts that were formally affiliated with each program. Administrative contacts, in turn, identified provider contacts who were successful in receiving reimbursement. The Aware program was the exception; that case study was limited to an administrative contact.

We developed one interview guide for administrative interviewees and another for providers, focused on details of the reimbursement mechanism, including the development of the mechanism, types of providers eligible to bill, and strengths and challenges of the mechanism. We then tailored each guide to the individual interviewee. Interviewees received a list of the discussion questions based on the interview guide in advance of the interview date. We conducted nine interview sessions with a total of 14 individuals, where several interviews included multiple interviewees. Interviews generally lasted 60 minutes and were conducted over Zoom. We recorded each interview and transcribed each using Temi. We reviewed the transcripts for key takeaways and common themes.