# 1. Background

According to the 2019 National Survey on Drug Use and Health, the prevalence of behavioral health (BH) conditions, including substance use disorders (SUDs) and mental health conditions, have remained stable, or increased, in recent years. Among adults aged 18 or older in 2019, 25% (61 million people) had either a mental health condition or an SUD in the past year. Unmet need for behavioral health services is also substantial.^1^ The unmet need for mental health services is especially striking in the population of adults with serious mental illness (SMI), where 48% of individuals reported experiencing an unmet need for mental health services. Among adults with co-occurring SUD and SMI, that need is even greater: only 13% received SUD treatment at a specialty facility and mental health services.

Widespread behavioral health workforce shortages and unequal distribution of providers contribute to the high levels of unmet need in behavioral health care.^2,3^ Additionally, the current workforce shortage is projected to worsen over the next decade. A recent Health Resources and Services Administration (HRSA) report provides national-level supply and demand projections for behavioral health professionals from 2017 through 2030. Current behavioral health workforce shortages (e.g., adult and child psychiatrists) are apparent in the 2017 data, and HRSA projects further reductions in the supply of psychiatrists and addiction counselors by 2030.^4^

The HRSA report on workforce projections emphasizes the importance of health care delivery models that increase the use of peers, paraprofessionals, and non-licensed behavioral health workers to expand the workforce. Team-based care models typically involve two or more individuals of varying disciplines and backgrounds who work collaboratively to provide coordinated behavioral health care. A team-based approach can help address behavioral health workforce shortages by allowing peers and non-licensed behavioral health workers to work alongside licensed professional providers, in turn allowing licensed professionals to practice at the top of their license. Team-based care can provide other advantages as well: through increased care coordination and improved care integration, it can reduce burnout for providers and enhance comprehensive care for patients.^5,6^ In addition, recent studies have shown that team-based care helps to improve patient satisfaction^7^ and the quality, utilization, and cost of care.^8^

Despite these potential benefits, experts have noted that many reimbursement mechanisms do not adequately support team-based care models. They may not account for the time spent coordinating and meeting as team.^9^ Additionally, many existing licensing, credentialing, and payment policies limit the ability of peers and non-licensed behavioral health workers to independently bill for services rendered.^10^ Several evidence-based services, service delivery mechanisms, and promising practices, such as Assertive Community Treatment (ACT), the Collaborative Care Model (CoCM), and mobile crisis teams (MCTs), require multidisciplinary teams that include peer support specialists and non-licensed counselors. Some established reimbursement mechanisms support these team-based models, but reimbursement approaches vary widely.

The goal of this study is to better understand the adoption and implementation of team-based care and existing reimbursement mechanisms across Medicaid, Medicare, and commercial payers. Specifically, this study aims to answer the following research questions:

1. What reimbursement mechanisms exist for common evidence-based behavioral health models that use teams of providers, especially peers and counselors?
2. What strategies allow, encourage, or require coverage of team-based services in Medicaid, Medicare, and commercial payers?

This report presents findings from an environmental scan, subject matter expert interviews, a catalog of reimbursement mechanisms used in team-based behavioral health care, and case studies of five selected service models with varying approaches to team-based reimbursement. The first section of this report presents methods and findings of the environmental scan and reimbursement catalog, followed by a section dedicated to the case study findings. Finally, the results from both sections are synthesized to outline key strategies to support reimbursement of team-based behavioral health care.