# Appendix A Technical Details

Information gathered in our searches was organized into an Excel spreadsheet. The spreadsheet includes fields for team composition, services, reimbursement mechanisms, and other model details. The team composition field describes the types of providers typically involved in each model, including physicians, nurses, counselors and therapists, social workers, case managers or care coordinators, and peers. In parallel with team composition, the services field details the clinical, psychosocial, and coordinative components of care provided by each model. Reimbursement mechanisms (e.g., FFS, bundled payments) were tracked in reimbursement fields along with funding sources, which included payers (Medicaid, commercial insurance) and other sources like grants. Other fields categorized the models by their populations served (adult, youth, or child), most common setting (e.g., hospital, outpatient practice, telehealth, community, home), and focus (SUD, mental health, or general behavioral health). Models were also subjectively tagged as established or emergent based upon their date of inception and their prevalence.

We operationalized our search using the base terms “team-based care” OR “team-based care model” were combined with each of the following terms for a total of four searches: “behavioral health”; “substance-use disorder” OR SUD; “mental health”; and “behavioral health” AND “Peer.” These four searches were applied to Google and Google Scholar. Four additional searches were conducted in each search engine using those terms plus the following reimbursement-focused phrases: “reimbursement mechanism”; “value-based payment” OR “value-based purchasing” OR “capitated payment”; Medicaid OR Medicare OR Commercial OR Private OR Payer; and “Coordinated Specialty Care (CSC)” OR “Assertive Community Treatment (ACT)” OR “Opioid Home Health” OR “Mobile Crisis.” Each of these eight searches was conducted within two timeframes, 2010+ and anytime, for a total of 16 search combinations. Due to Google’s word limit on queries, the terms for each reimbursement-focused search were divided into three separate searches, within the general Internet search.