# Executive Summary

## Background

About 12 million people in the United States have peripheral arterial disease (PAD) and it is increasing in frequency. In the lower extremities, PAD affects three major arterial segments: aorto-iliac arteries, femoral popliteal arteries, and infrapopliteal (primarily tibial) arteries. The disease is commonly classified clinically based on claudication, rest pain, or degree of tissue loss due to chronic ischemia. Treatment is based on lifestyle changes, including exercise, and medications to improve blood flow. Patients with more severe clinical disease often require invasive interventions aimed at reestablishing bloodflow to the affected limbs.

Invasive treatment options include open surgery of the lower extremity with either autogenous or synthetic grafts to bypass the arterial occlusion(s), endarterectomy, and catheter-based endovascular procedures. These latter procedures include percutaneous transluminal angioplasty (where the vessel lumen is expanded at the site of the occlusion with a balloon), balloon-expandable stents (which are left in place to support the opened lumen), and more recently self-expanding stents, in addition to other less commonly used interventions or cointerventions such as brachytherapy, cryotherapy, drug-eluting stents, and atherectomy.

In 2007, the Transatlantic Intersociety Consensus (TASC) Committee updated a consensus document on managing lower extremity PAD. TASC II updated a classification scheme for the disease based on anatomy of the disease and the extent of lesions. Treatment recommendations were established for the four classifications (A to D). The American College of Cardiology (ACC) and the American Heart Association (AHA) also published recommendations in 2006 based on clinical symptoms and anatomic level of disease.

The Centers for Medicare and Medicaid Services (CMS) has requested a technology assessment report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ) on invasive interventions to treat occlusive lesions related to PAD, focusing primarily on peripheral artery angioplasty with stent placement. For this topic, CMS is primarily interested in clinical outcomes, in contradistinction to the most commonly researched outcome in the field of PAD, artery patency. AHRQ assigned this report to the following Evidence-based Practice Center: Tufts Evidence-based Practice Center (Contract No. HHSA-290-2007-10055-1-EPC3).

## Key Questions

1. Perform horizon scan of published literature on invasive vascular procedures for the treatment of infrarenal PAD (surgical bypass grafting, angioplasty, angioplasty with stent placement, atherectomy). Categorize studies based on intervention; preoperative characteristics of PAD defined by clinical, anatomic, and hemodynamic features (based primarily on TASC II classification schemes); primary outcomes; study design; and sample size.
2. Review and describe the studies cited in the TASC II report that support the recommendations regarding choice of intervention. Judge whether the cited studies adequately support the recommendations.
3. Perform a systematic review across invasive vascular interventions for infrarenal PAD for the association between the TASC I or II classification schemes and rates of clinical outcomes (mortality, amputation, clinical stage, reinterventions, and quality of life) after the intervention, accounting for differences in anatomy and interventions.
4. Perform systematic review of the relative safety and effect of peripheral artery stenting with other invasive vascular procedures for occlusive PAD of infrarenal vessels. Also evaluate comparisons of different stents and/or different procedures with stents. Among comparative studies (stent versus other intervention; stent versus stent) evaluate the following questions and features:
  - Methodological quality of studies
  - Applicability of studies to patients aged ≥65 years with occlusive PAD (based on the CMS population)
  - Demographic and other preoperative (baseline) features of studied patients
  - Clinical, anatomic, and hemodynamic features of PAD lesions (based primarily on TASC II classification schemes)
  - Types of the stents used (specifically discussing steel, nitinol, drug eluting and other stents in this rapidly evolving field)
  - Concurrent and postoperative treatments, including but not limited to brachytherapy and antiplatelet therapy
  - Length of followup
  - Persistence of effects over time
  - Clinical outcomes (patient survival, limb salvage, primary patency, primary assisted patency, secondary patency, pain, quality of life)
  - Adverse events

## Conclusions

### Key Question 1: Horizon scan of invasive vascular procedures for PAD

The horizon scan evaluated the evidence on invasive vascular procedures for PAD at the level of study abstracts and titles. From a literature search conducted in MEDLINE and the Cochrane Clinical Trial Registry on July 19, 2007, we included citations of studies or systematic reviews of at least 10 patients with chronic lower extremity PAD with any invasive vascular procedure. The literature searches yielded 14,815 citations, of which 2,488 reported data on primary studies of invasive interventions for lower extremity PAD.

Single arm studies represented 79 percent of articles; only 5 percent were randomized controlled trials (RCTs) and 9 percent were nonrandomized comparative studies. Almost 570,000 patients have been evaluated in the literature to date; about 3 percent in RCTs. Among abstracts reporting the data, median followup time was 18 months in RCTs and 24 months in comparative studies and single arm studies. Fifteen percent of the studies have been published since 2000.

RCTs tended to be conducted in patients with femoral popliteal disease (67 percent) or combination artery disease (20 percent). In contrast nonrandomized studies included a greater variety of disease, with only one-third of patients with femoral popliteal disease. Only 3 percent of studies reported TASC classification in their abstracts; of these, the large majority included patients with more severe disease (grade C or D); only 10 percent included only patients with grade A or B.

Almost half the articles pertained to surgical bypass, 40 percent to PTA, about one-sixth stent, and one-ninth atherectomy. About one-quarter of RCTs evaluated stent, one-half PTA, and one-half bypass. Only one-third compared different types of interventions (e.g., PTA versus stent). Among the 80 percent of abstracts that reported data on which outcomes were evaluated, imaging success (e.g., patency) was most commonly reported (69 percent), particularly among RCTs (84 percent). Complications, mortality, amputations, and hemodynamic success were reported in approximately one-third of abstracts, symptomatic relief and reinterventions were reported in about one-fifth, and quality of life and economic evaluations were rarely reported. Overall, 38 percent of studies reported clinical outcomes in their abstracts. Though, three-quarters of the comparative studies reported clinical outcomes. Only about a third of the studies reported complication rates in their abstracts, though it is likely that this underestimates the reporting of adverse events in the publications.

In summary, the study publications on invasive interventions for lower extremity PAD are heavily weighted toward single arm (noncomparative) studies of PTA and bypass surgery. Among the comparative studies, most evaluated comparisons between different bypass or different PTA interventions. Relatively few studies compared different categories of interventions. To inform clinicians, patients, and policymakers of the relative value of different techniques, the area that may be most fruitful for summarizing appears to be the comparison between PTA and stent. Reviews of comparative studies of atherectomy or of brachytherapy are likely to be premature, given the small number of publications. Most studies appear to have followed patients for a reasonable period of time (at least 18 months), but there has been a disproportionate use of imaging outcomes instead of clinically meaningful outcomes. Future systematic reviews of topics with multiple interventions, patient differences (such as anatomy of disease), and outcomes of interest could well benefit from preliminary horizon scans to help focus (or expand) topics and key questions for the subsequent systematic reviews.

### Key Question 2: Review of TASC II report

Our review provides a brief synopsis of the studies that were cited as evidence and the strength of the evidence for each of the TASC recommendations, and a detailed examination of the anatomic descriptions of the atherosclerotic process in each of the studies. Our expectation was that the studies cited as evidence supporting the recommendations would have an anatomic description of the patients treated by a specific therapy. Preferably, the outcomes measured by the studies to assess the effect of the interventions should have been clinically based.

The cited aorto-iliac surgery studies did not describe the preoperative anatomy and no clinically relevant outcomes were reported. The majority of studies cited for the endovascular treatment of the aorto-iliac segment did have anatomic descriptions of the studied patients, but none used the TASC classification. Most studies did report on clinical outcomes. Similarly, studies cited for recommending endovascular treatment of femoral popliteal disease mostly did not provide sufficiently adequate anatomic descriptions of the involved segment to categorize by TASC classification. Clinically relevant outcomes, however, were employed in almost all of the studies. However, it was striking that only a minority of the relevant evidence for endovascular treatment of PAD was cited by the TASC II report.

### Key Question 3: Systematic review of TASC classification and clinical outcomes

Thirty-one studies reported TASC classification and clinical outcomes after an invasive intervention for lower extremity PAD. The specific details of how the TASC classification of each patient was determined were generally not reported.

Eleven studies directly compared outcomes among TASC grades or between bypass and PTA for a specific TASC grade population. Only six of these, though, reported statistical analyses related to TASC classification. Three studies compared bypass to PTA with or without stenting, but did not find evidence that any procedure resulted in better clinical outcomes based on TASC classification. Across studies with direct comparisons of TASC classifications, there were trends suggesting that patients with higher levels of disease had worse clinical outcomes, though the studies were underpowered to detect differences. Indirect comparisons across studies were performed, but the studies were too heterogeneous to reach conclusions as to which treatment results in better clinical outcomes based on TASC classification.

### Key Question 4: Systematic review of comparative stent studies

From the 14,815 citations, 82 articles potentially met eligibility criteria based on their abstracts and were retrieved for review; one additional RCT was added by domain experts. Among these, 27 studies (in 33 publications) met criteria, including 13 RCTs, 4 prospective comparative studies, and 10 retrospective comparative studies. The studies, in general, and the trials, specifically, were highly clinically heterogeneous regarding the type of stent used, the (selective) use of stent placement as a secondary intervention in the PTA arm (crossover), the severity and anatomy of PAD, the proportion of patients with cardiovascular risk factors, the dates of the interventions, the duration of followup, and the outcomes assessed.

Ten RCTs, 3 prospective and 8 retrospective comparative studies evaluated stent versus PTA. The studies primarily evaluated patients with femoral popliteal disease. The RCTs mostly used balloon expandable stents, though nonrandomized studies often evaluated self-expanding stents. One RCT and two retrospective studies compared bypass to stents. Two RCTs and one prospective comparative study compared different stents.

Individual studies did find statistically significantly better clinical outcomes with one intervention or the other, but overall, the trials and other comparative studies failed to provide adequate data to show that any one intervention is superior for any outcome over any other intervention in any group of patients. However, for the most part, the data cannot be said to convincingly show that stent and PTA (or the other comparisons) are equivalent. The studies are clinically too heterogeneous and both individually and collectively too small to accurately estimate relative differences in clinical event rates.

There is a dearth of trials of patients with either aorto-iliac or infrapopliteal disease. The newer nitinol stents were used by only three of the trials (plus one RCT of stent versus bypass and two RCTs comparing different stents). The predominant primary outcome of the trials remains patency (variously defined), which has not been adequately shown to be an excellent predictor of clinical outcomes. True clinical outcomes have frequently been inadequately or incompletely reported and analyzed.

To be able to assess the true relative value of stent placement compared to PTA, it is important that future trials analyze more clearly defined questions, use greater methodological rigor, and use appropriate clinical outcomes. This includes clearly defining what the population being analyzed is (by diseased artery, lesion morphology, and clinical severity) and what the intervention and comparator is (preferably analyzing stent to PTA, with minimal crossover, since high rates of secondary stenting make the study results difficult to interpret). The primary outcomes should be important clinical outcomes, not surrogate outcomes such as patency (or even ABI). Researchers should choose the best standardized, clinically meaningful and useful measures of outcomes, particularly for potentially subjective outcomes such as “clinical status.” Trials should be adequately powered to fully evaluate these clinical outcomes, with allowance made to capture long-term followup. And complications and other safety outcomes should be fully and actively solicited and analyzed. Until high quality trials are published that address these issues and study the patients for whom the interventions are actually being used, the value of stent placement compared to PTA for patients with PAD will remain unclear.