# References

1 Future of vascular services. Strategic forecast and investment blueprint. The Advisory Board Company. 2005.
2 Anderson PL, Gelijns A, Moskowitz A, et al. Understanding trends in inpatient surgical volume: vascular interventions, 1980–2000. J Vase Surg. 2004;39:1200-1208.
3 Selvin E, Erlinger TP. Prevalence of and risk factors for peripheral arterial disease in the United States: results from the National Health and Nutrition Examination Survey, 1999–2000. Circulation. 2004;110:738-743. [pmid: 15262830].
4 Nowygrod R, Egorova N, Greco G, et al. Trends, complications, and mortality in peripheral vascular surgery. J Vase Surg. 2006;43:205-216.
5 Rutherford RB, Baker JD, Ernst C, et al. Recommended standards for reports dealing with lower extremity ischemia: revised version. J Vase Surg. 1997;26:517-538.
6 Fontaine R, Kim M, Kieny R. [Surgical treatment of peripheral circulation disorders]. [German]. Helv Chir Acta. 1954;21:499-533. [pmid: 14366554].
7 Strandness DE Jr, Sumner DS. Hemodynamics for surgeons. New York. Grune & Stratton. 1975.
8 Rutherford RB, Becker GJ. Standards for evaluating and reporting the results of surgical and percutaneous therapy for peripheral arterial disease. J Vase Interv Radiol. 1991;2:169-174.
9 Strandness DE Jr, Schultz RD, Sumner DS, Rushmer RF. Ultrasonic flow detection. A useful technic in the evaluation of peripheral vascular disease. American Journal of Surgery. 1967;113:311-320. [pmid: 6018677].
10 Carter SA. Response of ankle systolic pressure to leg exercise in mild or questionable arterial disease. New England Journal of Medicine. 1972;287:578-582. [pmid: 5055207].
11 Raines JK, Darling RC, Buth J, Brewster DC, Austen WG. Vascular laboratory criteria for the management of peripheral vascular disease of the lower extremities. Surgery. 1976;79:21-29. [pmid: 1246689].
12 Fleischmann D, Lammer J. Peripheral CT angiography for interventional treatment planning. Eur Radiol. 2006;16:M58-M64. [pmid: 18655268].
13 O'Donnell TF Jr, Lahey SJ, Kelly JJ, et al. A prospective study of Doppler pressures and segmental plethysmography before and following aortofemoral bypass. Implications for predicting success and for adopting a uniform method of classifying arterial disease. Surgery. 1979;86:120-129. [pmid: 451884].
14 Boyd AM. The natural course of arteriosclerosis of the lower extremities. Proceedings of the Royal Society of Medicine. 1962;55:591-593. [pmid: 13872137].
15 Management of peripheral arterial disease (PAD). TransAtlantic Inter-Society Consensus (TASC). Eur J Vase Endovasc Surg. 2000;19:S1-S250.
16 Coran AG, Warren R. Arteriographic changes in femoropopliteal arteriosclerosis obliterans. A five-year follow-up study. New England Journal of Medicine. 1966;274:643-647. [pmid: 17926375].
17 Brewster DC, Darling RC. Optimal methods of aortoiliac reconstruction. Surgery. 1978;84:739-748. [pmid: 152480].
18 Veith FJ, Gupta SK, Ascer E, et al. Six-year prospective multicenter randomized comparison of autologous saphenous vein and expanded polytetrafluoroethylene grafts in infrainguinal arterial reconstructions. Journal of Vascular Surgery. 1986;3:104-114. [pmid: 3510323].
19 Berglund J, Bjorck M, Elfstrom J. SWEDVASC Femoro-popliteal Study Group. Long-term results of above knee femoro-popliteal bypass depend on indication for surgery and graft-material. Eur J Vase Endovasc Surg. 2005;29:412-418.
20 Harris PL, Veith FJ, Shanik GD, Nott D, Wengerter KR, Moore DJ. Prospective randomized comparison of in situ and reversed infrapopliteal vein grafts. Br J Surg. 1993;80:173-176. [pmid: 8443642].
21 van der Heijden FH, Eikelboom BC, van Reedt Dortland RW, et al. Endarterectomy of the superficial femoral artery: a procedure worth reconsidering. European Journal of Vascular Surgery. 1992;6:651-658. [pmid: 1451824].
22 Moll FL, Ho GH. Closed superficial femoral artery endarterectomy: a 2-year follow-up. Cardiovascular Surgery. 1997;5:398-400. [pmid: 9350795].
23 Martin JD, Hupp JA, Peeler MO, Warble PB. Remote endarterectomy: lessons learned after more than 100 cases. J Vase Surg. 2006;43:320-326.
24 Derksen WJ, Gisbertz SS, Pasterkamp G, De Vries JP, Moll FL. Remote superficial femoral artery endarterectomy. J Cardiovasc Surg (Torino). 2008;49:193-198.
25 Antoniou GA, Koutsias S, Antoniou SA, Giannoukas AD. Remote endarterectomy for long segment superficial femoral artery occlusive disease. A systematic review. Eur J Vase Endovasc Surg. 2008;36:310-318.
26 Norgren L, Hiatt WR, Dormandy JA, et al. Inter-Society Consensus for the Management of Peripheral Arterial Disease (TASC II). J Vase Surg. 2007;45:S5-S67.
27 Szilagyi DE, Hageman JH, Smith RF, Elliott JP, Brown F, Dietz P. Autogenous vein grafting in femoropopliteal atherosclerosis: the limits of its effectiveness. Surgery. 1979;86:836-851. [pmid: 515951].
28 Timaran CH, Prault TL, Stevens SL, Freeman MB, Goldman MH. Iliac artery stenting versus surgical reconstruction for TASC (TransAtlantic Inter-Society Consensus) type B and type C iliac lesions. J Vase Surg. 2003;38:272-278.
29 Dotter CT, Judkins MP. Transluminal treatment of arteriosclerotic obstruction. Description of a new technic and a preliminary report of its application. Circulation. 1964;30:654-670. [pmid: 14226164].
30 Bollinger A, Schlumpf M. Andreas Gruntzig's balloon catheter for angioplasty of peripheral arteries (PTA) is 25 years old. Vasa. 1999;28:58-64. [pmid: 10191711].
31 Bosch JL, Hunink MG. Meta-analysis of the results of percutaneous transluminal angioplasty and stent placement for aortoiliac occlusive disease. Radiology. 1997;204:87-96. [pmid: 9205227].
32 Waller BF, Dillon JC, Cowley MH. Plaque hematoma and coronary dissection with percutaneous transluminal angioplasty (PTCA) of severely stenotic lesions: morphologic coronary observations in 5 men within 30 days of PTCA. Circulation. 1983;68:111S-144S.
33 Samson RH, Showalter DP, Lepore M Jr, Nair DG, Merigliano K. CryoPlasty therapy of the superficial femoral and popliteal arteries: a reappraisal after 44 months' experience. J Vase Surg. 2008;48:634-637.
34 McCaslin JE, Macdonald S, Stansby G. Cryoplasty for peripheral vascular disease. Cochrane Database Syst Rev. 2007:CD005507. [pmid: 17943861].
35 Dolmatch BL, Tio FO, Li XD, Dong YH. Patency and tissue response related to two types of polytetrafluoroethylene-covered stents in the dog. J Vase Interv Radiol. 1996;7:641-649.
36 Iida O, Nanto S, Uematsu M, et al. Effect of exercise on frequency of stent fracture in the superficial femoral artery. American Journal of Cardiology. 2006;98:272-274. [pmid: 16828607].
37 Scheinert D, Scheinert S, Sax J, et al. Prevalence and clinical impact of stent fractures after femoropopliteal stenting. J Am Coll Cardiol. 2005;45:312-315. [pmid: 15653033].
38 Schlager O, Dick P, Sabeti S, et al. Long-segment SFA stenting--the dark sides: in-stent restenosis, clinical deterioration, and stent fractures. J Endovasc Ther. 2005;12:676-684. [pmid: 16363897].
39 Jaff M, Dake M, Pompa J, Ansel G, Yoder T. Standardized evaluation and reporting of stent fractures in clinical trials of noncoronary devices. Catheter Cardiovasc Interv. 2007;70:460-462. [pmid: 17559108].
40 Krankenberg H, Schluter M, Steinkamp HJ, et al. Nitinol stent implantation versus percutaneous transluminal angioplasty in superficial femoral artery lesions up to 10 cm in length: the femoral artery stenting trial (FAST). Circulation. 2007;116:285-292. [pmid: 17592075].
41 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic. Circulation. 2006;113:e463-e654. [pmid: 16549646].
42 Labs KH, Dormandy JA, Jaeger KA, Stuerzebecher C, Hiatt WR. Trans-atlantic conference on clinical trial guidelines in PAOD (Peripheral arterial occlusive disease) clinical trial methodology. European Journal of Vascular & Endovascular Surgery. 1999;18:253-265. [pmid: 10480800].
43 Diehm N, Baumgartner I, Jaff M, et al. A call for uniform reporting standards in studies assessing endovascular treatment for chronic ischaemia of lower limb arteries. European Heart Journal. 2007;28:798-805. [pmid: 17317699].
44 Balk E, Raman G, Chung M, et al. Effectiveness of management strategies for renal artery stenosis: a systematic review. Ann Intern Med. 2006;145:901-912. [pmid: 17062633].
45 Clinical Practice Guidelines for Chronic Kidney Disease: Evaluation, Classificaiton, and Stratification. Am J Kid Dis. 2002;39.
46 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].
47 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21:1539-1558. [pmid: 12111919].
48 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. 2004;23:1351-1375. [pmid: 15116347].
49 Bradburn MJ, Deeks JJ, Berlin JA, Russell LA. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. 2007;26:53-77. [pmid: 16596572].
50 Reed AB, Conte MS, Donaldson MC, Mannick JA, Whittemore AD, Belkin M. The impact of patient age and aortic size on the results of aortobifemoral bypass grafting. Journal of Vascular Surgery. 2003;37:1219-1225. [pmid: 12764268].
51 de Vries SO, Hunink MG. Results of aortic bifurcation grafts for aortoiliac occlusive disease: a meta-analysis. Journal of Vascular Surgery. 1997;26:558-569. [pmid: 9357455].
52 Becker GJ, Katzen BT, Dake MD. Noncoronary angioplasty. Radiology. 1989;170:921-940. [pmid: 2521745].
53 Rutherford R, Durham J. Yao J, Pearce W, editors. Percutaneous balloon angioplasty for arteriosclerosis obliterans: long term results. Techniques in Vascular Surgery. Philadelphia. Saunders. 1992:329-345.
54 Murphy TP, Ariaratnam NS, Carney WI Jr, et al. Aortoiliac insufficiency: long-term experience with stent placement for treatment. Radiology. 2004;231:243-249. [pmid: 15068949].
55 Bosch JL, van der Graaf Y, Hunink MG. Health-related quality of life after angioplasty and stent placement in patients with iliac artery occlusive disease: results of a randomized controlled clinical trial. The Dutch Iliac Stent Trial Study Group. Circulation. 1999;99:3155-3160. [pmid: 10377079].
56 Klein WM, van der Graaf Y, Seegers J, et al. Dutch iliac stent trial: long-term results in patients randomized for primary or selective stent placement. Radiology. 2006;238:734-744. [pmid: 16371580].
57 Tetteroo E, Haaring C, van der Graaf Y, van Schaik JP, van Engelen AD, Mali WP. Intraarterial pressure gradients after randomized angioplasty or stenting of iliac artery lesions. Dutch Iliac Stent Trial Study Group. Cardiovasc Intervent Radiol. 1996;19:411-417. [pmid: 8994707].
58 Ponec D, Jaff MR, Swischuk J, et al. The Nitinol SMART stent vs Wallstent for suboptimal iliac artery angioplasty: CRISP-US trial results. J Vase Interv Radiol. 2004;15:911-918.
59 Adam DJ, Beard JD, Cleveland T, et al. Bypass versus angioplasty in severe ischaemia of the leg (BASIL): multicentre, randomised controlled trial. Lancet. 2005;366:1925-1934. [pmid: 16325694].
60 Wolf GL, Wilson SE, Cross AP, Deupree RH, Stason WB. Surgery or balloon angioplasty for peripheral vascular disease: a randomized clinical trial. Principal investigators and their Associates of Veterans Administration Cooperative Study Number 199. Journal of Vascular & Interventional Radiology. 1993;4:639-648. [pmid: 8219559].
61 Muradin GS, Bosch JL, Stijnen T, Hunink MG. Balloon dilation and stent implantation for treatment of femoropopliteal arterial disease: meta-analysis. Radiology. 2001;221:137-145. [pmid: 11568332].
62 Aarts F, Blankensteijn JD, van D V, Kool LJ. Subintimal angioplasty of supra- and infrageniculate arteries. Ann Vase Surg. 2006;20:620-624.
63 Ali AT, Modrall JG, Lopez J, et al. Emerging role of endovascular grafts in complex aortoiliac occlusive disease. J Vase Surg. 2003;38:486-491.
64 Alimi YS, De CG, Hartung O, et al. Laparoscopy-assisted reconstruction to treat severe aortoiliac occlusive disease: early and midterm results. J Vase Surg. 2004;39:777-783.
65 Balzer JO, Gastinger V, Ritter R, et al. Percutaneous interventional reconstruction of the iliac arteries: primary and long-term success rate in selected TASC C and D lesions. European Radiology. 2006;16:124-131. [pmid: 15809828].
66 Coggia M, Javerliat I, Di CI, et al. Total laparoscopic bypass for aortoiliac occlusive lesions: 93-case experience. J Vase Surg. 2004;40:899-906.
67 Costanza MJ, Queral LA, Lilly MP, Finn WR. Hemodynamic outcome of endovascular therapy for TransAtlantic InterSociety Consensus type B femoropopliteal arterial occlusive lesions. J Vase Surg. 2004;39:343-350.
68 Dion YM, Griselli F, Douville Y, Langis P. Early and mid-term results of totally laparoscopic surgery for aortoiliac disease: lessons learned. Surg Laparosc Endosc Percutan Tech. 2004;14:328-334. [pmid: 15599296].
69 Dippel E, Shammas N, Takes V, Coyne L, Lemke J. Twelve-month results of percutaneous endovascular reconstruction for chronically occluded superficial femoral arteries: a quality-of-life assessment. J Invasive Cardiol. 2006;18:316-321. [pmid: 16816437].
70 Duda SH, Pusich B, Richter G, et al. Sirolimus-eluting stents for the treatment of obstructive superficial femoral artery disease: six-month results. Circulation. 2002;106:1505-1509. [pmid: 12234956].
71 Fourneau I, Daenens K, Nevelsteen A. Hand-assisted laparoscopic aortobifemoral bypass for occlusive disease. Early and mid-term results. Eur J Vase Endovasc Surg. 2005;30:489-493.
72 Fourneau I, Sabbe T, Daenens K, Nevelsteen A. Hand-assisted laparoscopy versus conventional median laparotomy for aortobifemoral bypass for severe aorto-iliac occlusive disease: a prospective randomised study. Eur J Vase Endovasc Surg. 2006;32:645-650.
73 Galaria II, Davies MG. Percutaneous transluminal revascularization for iliac occlusive disease: long-term outcomes in TransAtlantic Inter-Society Consensus A and B lesions. Ann Vase Surg. 2005;19:352-360.
74 Greiner A, Dessl A, Klein-Weigel P, et al. Kissing stents for treatment of complex aortoiliac disease. Eur J Vase Endovasc Surg. 2003;26:161-165.
75 Hynes N, Akhtar Y, Manning B, et al. Subintimal angioplasty as a primary modality in the management of critical limb ischemia: comparison to bypass grafting for aortoiliac and femoropopliteal occlusive disease. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2004;11:460-471.
76 Kedora J, Hohmann S, Garrett W, Munschaur C, Theune B, Gable D. Randomized comparison of percutaneous Viabahn stent grafts vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral arterial occlusive disease. J Vase Surg. 2007;45:10-16.
77 Keeling WB, Shames ML, Stone PA, et al. Plaque excision with the Silverhawk catheter: early results in patients with claudication or critical limb ischemia. Journal of Vascular Surgery. 2007;45:25-31. [pmid: 17210379].
78 Kim JS, Kang TS, Ahn CM, et al. Efficacy of subintimal angioplasty/stent implantation for long, multisegmental lower limb occlusive lesions in patients unsuitable for surgery. J Endovasc Ther. 2006;13:514-521. [pmid: 16928168].
79 Kudo T, Chandra FA, Ahn SS. Long-term outcomes and predictors of iliac angioplasty with selective stenting. J Vase Surg. 2005;42:466-475.
80 Laird J, Jaff MR, Biamino G, et al. Cryoplasty for the treatment of femoropopliteal arterial disease: results of a prospective, multicenter registry. Journal of Vascular & Interventional Radiology. 2005;16:1067-1073. [pmid: 16105918].
81 Lauterbach SR, Torres GA, Andros G, Oblath RW. Infragenicular polytetrafluoroethylene bypass with distal vein cuffs for limb salvage: a contemporary series. Arch Surg. 2005;140:487-493. [pmid: 15897445].
82 Lazaris AM, Tsiamis AC, Fishwick G, Bolia A, Bell PR. Clinical outcome of primary infrainguinal subintimal angioplasty in diabetic patients with critical lower limb ischemia. J Endovasc Ther. 2004;11:447-453. [pmid: 15298514].
83 Leville CD, Kashyap VS, Clair DG, et al. Endovascular management of iliac artery occlusions: extending treatment to TransAtlantic Inter-Society Consensus class C and D patients. Journal of Vascular Surgery. 2006;43:32-39. [pmid: 16414384].
84 Piffaretti G, Tozzi M, Lomazzi C, et al. Mid-term results of endovascular reconstruction for aorto-iliac obstructive disease. Int Angiol. 2007;26:18-25. [pmid: 17353884].
85 Rosenthal D, Martin JD, Smeets L, et al. Remote superficial femoral artery endarterectomy and distal aSpire stenting: results of a multinational study at three-year follow-up. J Cardiovasc Surg (Torino). 2006;47:385-391.
86 Safley DM, House JA, Laster SB, Daniel WC, Spertus JA, Marso SP. Quantifying improvement in symptoms, functioning, and quality of life after peripheral endovascular revascularization. Circulation. 2007;115:569-575. [pmid: 17242281].
87 Sigala F, Menenakos C, Sigalas P, et al. Transluminal angioplasty of isolated crural arterial lesions in diabetics with critical limb ischemia. Vasa. 2005;34:186-191. [pmid: 16184838].
88 Surowiec SM, Davies MG, Eberly SW, et al. Percutaneous angioplasty and stenting of the superficial femoral artery. Journal of Vascular Surgery. 2005;41:269-278. [pmid: 15768009].
89 Tefera G, Hoch J, Turnipseed WD. Limb-salvage angioplasty in vascular surgery practice. Journal of Vascular Surgery. 2005;41:988-993. [pmid: 15944598].
90 Trocciola SM, Chaer R, Dayal R, et al. Comparison of results in endovascular interventions for infrainguinal lesions: claudication versus critical limb ischemia. Am Surg. 2005;71:474-479. [pmid: 16044925].
91 Vogel TR, Shindelman LE, Nackman GB, Graham AM. Efficacious use of nitinol stents in the femoral and popliteal arteries. J Vase Surg. 2003;38:1178-1184.
92 Yancey AE, Minion DJ, Rodriguez C, Patterson DE, Endean ED. Peripheral atherectomy in TransAtlantic InterSociety Consensus type C femoropopliteal lesions for limb salvage. J Vase Surg. 2006;44:503-509.
93 Becquemin JP, Favre JP, Marzelle J, Nemoz C, Corsin C, Leizorovicz A. Systematic versus selective stent placement after superficial femoral artery balloon angioplasty: a multicenter prospective randomized study. J Vase Surg. 2003;37:487-494.
94 Cejna M, Thurnher S, Illiasch H, et al. PTA versus Palmaz stent placement in femoropopliteal artery obstructions: a multicenter prospective randomized study. J Vase Interv Radiol. 2001;12:23-31.
95 Tetteroo E, van der Graaf Y, Bosch JL, et al. Randomised comparison of primary stent placement versus primary angioplasty followed by selective stent placement in patients with iliac-artery occlusive disease. Dutch Iliac Stent Trial Study Group. Lancet. 1998;351:1153-1159. [pmid: 9643685].
96 Klein WM, van der Graaf Y, Seegers J, Moll FL, Mali WP. Long-term cardiovascular morbidity, mortality, and reintervention after endovascular treatment in patients with iliac artery disease: The Dutch Iliac Stent Trial Study. Radiology. 2004;232:491-498. [pmid: 15286319].
97 Duda SH, Bosiers M, Lammer J, et al. Drug-eluting and bare nitinol stents for the treatment of atherosclerotic lesions in the superficial femoral artery: long-term results from the SIROCCO trial. J Endovasc Ther. 2006;13:701-710. [pmid: 17154704].
98 Grimm J, Muller-Hulsbeck S, Jahnke T, Hilbert C, Brossmann J, Heller M. Randomized study to compare PTA alone versus PTA with Palmaz stent placement for femoropopliteal lesions. J Vase Interv Radiol. 2001;12:935-942.
99 Rand T, Basile A, Cejna M, et al. PTA versus carbofilm-coated stents in infrapopliteal arteries: pilot study. Cardiovasc Intervent Radiol. 2006;29:29-38. [pmid: 16252079].
100 Saxon RR, Coffman JM, Gooding JM, Natuzzi E, Ponec DJ. Long-term results of ePTFE stent-graft versus angioplasty in the femoropopliteal artery: single center experience from a prospective, randomized trial. J Vase Interv Radiol. 2003;14:303-311.
101 Schillinger M, Sabeti S, Loewe C, et al. Balloon angioplasty versus implantation of nitinol stents in the superficial femoral artery. N Engl J Med. 2006;354:1879-1888. [pmid: 16672699].
102 Schillinger M, Sabeti S, Dick P, et al. Sustained benefit at 2 years of primary femoropopliteal stenting compared with balloon angioplasty with optional stenting. Circulation. 2007;115:2745-2749. [pmid: 17502568].
103 Vroegindeweij D, Vos LD, Tielbeek AV, Buth J, vd Bosch HC. Balloon angioplasty combined with primary stenting versus balloon angioplasty alone in femoropopliteal obstructions: A comparative randomized study. Cardiovasc Intervent Radiol. 1997;20:420-425. [pmid: 9354709].
104 Wolfram RM, Budinsky AC, Pokrajac B, Potter R, Minar E. Vascular brachytherapy with 192Ir after femoropopliteal stent implantation in high-risk patients: twelve-month follow- up results from the Vienna-5 trial. Radiology. 2005;236:343-351. [pmid: 15987985].
105 Zdanowski Z, Albrechtsson U, Lundin A, et al. Percutaneous transluminal angioplasty with or without stenting for femoropopliteal occlusions? A randomized controlled study. Int Angiol. 1999;18:251-255. [pmid: 10811511].
106 Bosiers M, Hart JP, Deloose K, Verbist J, Peeters P. Endovascular therapy as the primary approach for limb salvage in patients with critical limb ischemia: experience with 443 infrapopliteal procedures. Vascular. 2006;14:63-69. [pmid: 16956473].
107 Do D-D, Triller J, Walpoth BH, Stirnemann P, Mahler F. A comparison study of self- expandable stents vs balloon angioplasty alone in femoropopliteal artery occlusions. Cardiovasc Intervent Radiol. 1992;15:306-312. [pmid: 1423391].
108 Schillinger M, Exner M, Mlekusch W, et al. Fibrinogen predicts restenosis after endovascular treatment of the iliac arteries. Thromb Haemost. 2002;87:959-965. [pmid: 12083502].
109 Siablis D, Kraniotis P, Karnabatidis D, Kagadis GC, Katsanos K, Tsolakis J. Sirolimus-eluting versus bare stents for bailout after suboptimal infrapopliteal angioplasty for critical limb ischemia: 6-month angiographic results from a nonrandomized prospective single-center study. J Endovasc Ther. 2005;12:685-695. [pmid: 16363898].
110 Siablis D, Karnabatidis D, Katsanos K, et al. Sirolimus-eluting versus bare stents after suboptimal infrapopliteal angioplasty for critical limb ischemia: enduring 1-year angiographic and clinical benefit. J Endovasc Ther. 2007;14:241-250. [pmid: 17484536].
111 Ballard JL, Bergan JJ, Singh P, Yonemoto H, Killeen JD. Aortoiliac stent deployment versus surgical reconstruction: analysis of outcome and cost. J Vase Surg. 1998;28:94-101.
112 Burns BJ, Phillips AJ, Fox A, Boardman P, Phillips-Hughes J. The timing and frequency of complications after peripheral percutaneous transluminal angioplasty and iliac stenting: is a change from inpatient to outpatient therapy feasible?. Cardiovasc Intervent Radiol. 2000;23:452-456. [pmid: 11232893].
113 Cho L, Roffi M, Mukherjee D, Bhatt DL, Bajzer C, Yadav JS. Superficial femoral artery occlusion: nitinol stents achieve better flow and reduce the need for medications than balloon angioplasty alone. J Invasive Cardiol. 2003;15:198-200. [pmid: 12668846].
114 Laxdal E, Wirsching J, Jenssen GL, Pedersen G, Aune S, Daryapeyma A. Endovascular treatment of isolated atherosclerotic lesions of the infrarenal aorta is technically feasible with acceptable long-term results. Eur J Radiol. 2007;61:541-544. [pmid: 17258418].
115 Pozzi Mucelli F, Fisicaro M, Calderan L, et al. Percutaneous revascularization of femoropopliteal artery disease: PTA and PTA plus stent. Results after six years' follow-up. Radiol Med (Torino). 2003;105:339-349. [pmid: 12835627].
116 Schillinger M, Mlekusch W, Haumer M, Sabeti S, Ahmadi R, Minar E. Angioplasty and elective stenting of de novo versus recurrent femoropopliteal lesions: 1-year follow-up. J Endovasc Ther. 2003;10:288-297. [pmid: 12877612].
117 Westcott MA, Bonn J. Comparison of conventional angioplasty with the Palmaz stent in the treatment of abdominal aortic stenoses from the STAR registry. SCVIR Transluminal Angioplasty and Revascularization. J Vase Interv Radiol. 1998;9:225-231.
118 Hays RD, Sherbourne CD, Mazel RM. The RAND 36-item health survey 1.0. Health Econ. 1993;2:217-227. [pmid: 8275167].
119 Duda SH, Bosiers M, Lammer J, et al. Sirolimus-eluting versus bare nitinol stent for obstructive superficial femoral artery disease: the SIROCCO II trial. J Vase Interv Radiol. 2005;16:331-338.
120 Katritsis DG, Ioannidis JP. Percutaneous coronary intervention versus conservative therapy in nonacute coronary artery disease: a meta-analysis. Circulation. 2005;111:2906-2912. [pmid: 15927966].
121 Agency for Health Care Policy and Research. Acute pain management: Operative or medical procedures and trauma [107]. Rockville MD. AHCPR. 1993.