# Discussion

## Horizon Scan

### Key Question 1 Perform horizon scan of published literature on invasive vascular procedures for the treatment of infrarenal PAD (surgical bypass grafting, angioplasty, angioplasty with stent placement, atherectomy). Categorize studies based on intervention; preoperative characteristics of PAD defined by clinical, anatomic, and hemodynamic features (based primarily on TASC II classification schemes26); primary outcomes; study design; and sample size

The systematic horizon scan of the vascular procedures for the treatment of PAD in the lower extremities gives clinicians, researchers, and policymakers a snapshot of the literature, which can be used to identity gaps in knowledge and can help to determine which questions are likely to have been addressed by the literature. The horizon scan gives a broad, but superficial, look at the interventions that have been evaluated, the study designs used, the populations included in studies, and an indication of the outcomes that have been reported. It is important to remember that the horizon scan was based on abstracts and titles, without delving into the full articles or attempting to remove multiple publications of the same studies. The frequencies of variables of interest are only as accurate and complete as what could be gleaned from the abstracts and titles. Notably, 11 percent of citations did not include abstracts, which may have led to an underestimation of the outcomes assessed as well as the number of studies that evaluated the safety of the interventions. However, most of the citations without abstracts were classified as having an unknown study design, and for the comparisons among study designs (where we did not consider the unknown design citations), at least 93 percent of citations had abstracts. Overall, it was common that information about patient characteristics, and even study designs or interventions, were either lacking or too unclear to assess. It also should be assumed that the outcomes reported in the abstracts underrepresent the outcomes analyzed in the full text articles. In general, the findings of the present horizon scan should not be used as an accurate indication of the adequacy of reporting or the quality of the studies.

#### Review of findings

With these caveats, the most common study design in the published PAD literature is the single arm study. For each intervention, published uncontrolled studies greatly outnumber comparative studies. An argument can be made that there are only a few situations in which a report of a single cohort of patients is of scientific value. One such is when the use of a comparator results in a known outcome rate. For example, if lack of treatment is universally fatal. In this situation, the relative benefit of the tested intervention (compared to the alternate treatment) can be confidently assessed. Data from single cohort studies could also be incorporated into properly adjusted regression analyses to determine predictors of favorable and unfavorable outcomes. In addition, if there is an incremental improvement in technique, then noncomparative studies may help advance clinical knowledge. For PAD interventions, the latter situation is more common, as there have been many incremental changes to surgical, angioplasty, and stent techniques and instrumentation. There is a clear value of disseminating this information without the effort of directly comparing new and old techniques. However, it is unlikely that the approximately 2,000 single arm studies that included hundreds of thousands of patients mostly represent improvements that could be put into practice by clinicians. Very few of the single arm studies reported evaluation of predictors of outcomes, whether properly adjusted or not. The clinical value, therefore, of the high volume of single arm studies is questionable.

The RCT is the best study design to evaluate efficacy and safety, but RCTs comprise only about 6 percent of the published literature and the sample sizes in these trials were small. The limited number and small sizes of these RCTs not only make the evaluation of the relative efficacy and safety of the interventions difficult, it also calls into question the reliability of the reported findings. A small sample size is likely to counteract the main goal of randomization, achieving groups with similar risks before the start of the intervention. These imbalances could lead to false positive results (concluding that one intervention is superior when it is not); though with small trials, in the setting of a true difference between interventions it is more likely that false negative results will occur, since confidence intervals will be large and statistical significance will be hard to achieve.

In the present horizon scan, we extracted from the abstracts whether or not authors reported statistically significant results as an indication that one intervention was superior to another. We found that 42 percent of studies reported statistically significant results. However, these findings could be misleading, since we counted any statistically significant result regardless of the importance of the outcomes. It is clear that authors preferentially report significant results in their abstracts.

The abstracts emphasized outcomes such as imaging – primarily aimed at patency and percent stenosis – or hemodynamic success. Only about one-third of abstracts reported clinical outcomes. It is plausible that patient-centered outcomes such as symptom relief or changes in quality of life were reported in the full publications but not in the abstracts. However, our analyses of the association between outcomes and TASC grade and our systematic review confirm that clinical outcomes are incompletely reported. There appears to be a reliance among study researchers on the concept that patency, or other surrogate outcomes, are a good indicator of long-term success for the investigated procedures. This is the case despite the unproven value of imaging success as a surrogate measure for clinical outcomes of importance to the patients.43 Besides being ingrained into both surgical and interventional radiologist literature as the standard there are several likely reasons for the continued frequent measurement of this outcome, including patency’s ease of measurement and that the use of patency allows for smaller numbers of patients to be enrolled for the same statistical power than clinical outcomes would require. In addition, there is the appeal of demonstrating that a once-blocked vessel can be successfully cleared. However, this has not been demonstrated for nonacute coronary artery disease120 nor possibly for renal artery stenosis;44 mechanical opening might not fully translate into improvement of symptoms. Fewer than a third of the studies reported hemodynamic success (in their abstracts). Despite consensus documents that encourage the use of clinical outcomes,4,44 fewer than a quarter of studies report symptomatic relief or need for reintervention. Very few studies report quality of life or economic evaluations, clearly important factors to help patients and clinicians to determine the best management. Only about a third of the studies report complication rates in their abstracts, though it is likely that this underestimates the reporting of adverse events in the publications. Nevertheless, given the potentially dire consequences of the more common complications from invasive arterial interventions, increased reporting of complications as primary outcomes would be of value.

Among the studies that reported followup durations, most followed patients for at least 18 to 24 months about a quarter followed patients for at least 3 years. For a simple assessment of the clinical value of the different interventions, this timeframe is adequate, but longer term followup, of at least 5 years, is needed to provide clinicians and patients with full information for decisionmaking regarding the optimal treatment.

Interestingly, RCTs were twice as likely to evaluate femoral popliteal disease as either nonrandomized comparative studies or single arm studies; however only 10 to 15 percent of studies reported disease anatomy in their abstracts. The explanation for this may simply be that the nonrandomized studies were more likely to take all-comers, instead of having strict eligibility criteria, thus these studies included many more patients with lesions in multiple vessels. This does suggest, however, that patients with aorto-iliac disease may be underrepresented among RCTs. Similarly, though severity of disease was difficult to assess, the horizon scan suggests that RCTs are substantially more likely to include patients with at most claudication (i.e., excluding critical limb ischemia) than noncomparative studies, suggesting an underrepresentation of this population also.

The interventions evaluated were fairly similar across study design types, with the exception that nonrandomized comparative studies were substantially more likely to evaluate surgical bypass than other study designs. Only about 17 percent of studies overall evaluated stent placement; almost half the studies evaluated PTA and/or evaluated bypass. Atherectomy has not been commonly studied. Other treatments have been rarely studied. The most common comparative studies were those in which one surgical intervention was compared to another. Other common comparisons have been between different versions of PTA, PTA versus stent, and (at least among nonrandomized studies) PTA versus bypass. Medical (noninvasive) interventions have been compared to PTA and bypass in 16 and 10 publications, respectively, but only with stents in 2 publications. Brachytherapy has been reported in abstracts of 33 primary studies (in conjunction with an invasive intervention). Overall, bypass surgery and PTA have been heavily studied, but the newer advances in therapy – stents, atherectomy, and brachytherapy – have relatively few studies. In part, this may be due to these therapies’ recent development; however, the continued dominance of publications on PTA over stents (and atherectomy) has continued at least through 2006.

The horizon scan demonstrated that there has been a change in research over time. Encouragingly, the exponential growth in single-arm studies stopped in about 1990, while there continues to be rapid growth in comparative studies. Currently, about 20 to 30 comparative studies are published annually. This may signify that frequent assessments for the need for updating any systematic reviews in the field are necessary. Systematic reviews have likewise been growing rapidly in number over the past decade. The interventions being investigated have also changed with time. The number of studies of stents has been growing exponentially since the late 1980, but these studies are still less common than those of PTA alone or bypass. Among single arm studies, the number of studies of PTA peaked in about 1990. For both single-arm and comparative studies, currently, approximately equal numbers of single arm studies of PTA and bypass are published annually. The proportion of studies evaluating different arteries has remained fairly constant since about 1990. Studies evaluating femoral popliteal arteries and those evaluating a combination of arteries are about twice as common as studies of the aorto-iliac arteries.

Finally, the majority of the studies appear to be broadly applicable to the Medicare population in that the average age of patients included in most studies is well over 65 years. Fewer than one-quarter of studies evaluated patients with mean ages below age 65. Relatively few studies excluded patients under age 65.

#### Horizon scan process

The main purpose of the horizon scan was to learn something about a large body of literature concerning a single topic in an efficient manner. In general, given limited resources, it would not be feasible to conduct a systematic review of all studies across such a large body of literature. A horizon scan permits an overview of the nature of the studies conducted concerning a broad topic. Data obtained from the horizon scan can help focus the formulation of the key questions that could reasonably be asked and answered from conducting a systematic review of relevant and qualifying studies.

Our horizon scan reviewed only data obtained from abstracts; this is not an unreasonable approach given the thousands of abstracts on peripheral arterial vascular interventions. Even though data obtained from abstracts are limited, it is vital that the horizon scan itself be conducted in a systematic manner; otherwise, the information obtained could be fragmented and may not be meaningful. To this end, the kinds of questions that should be asked before undertaking a horizon scan include: what elements of the body of literature are of interest and why? and how is the information gathered from such a scan to be used, given the inherent limitations of abstracts? The answers to these questions are dependent on who is asking the questions and who will use the information (e.g., researcher versus clinician versus payer versus patient versus advocacy group). Therefore, it is important to identify all the stakeholders prior to conducting a horizon scan so that all the relevant questions and issues could be raised and anticipated. Feedback from users of this report should inform future horizon scans.

Our horizon scan and systematic review were conducted as a single project. In the future, it may be preferable to perform a horizon scan first, and then using the results to inform a subsequent systematic review. Data gathered from the horizon scan could help to further refine key questions, by using the knowledge of what studies have been performed and understanding the kinds and quality of the data that are available. This process ought to minimize redundancy and promote efficiency.

We foresee two main challenges for using the horizon scan data. The first is to keep the horizon scan up to date so that policy makers, researchers, and health care providers can base their decisions on a current picture of the field. The second is to create ways to share the actual horizon scan with a greater community. It is crucial that stakeholders have access to the ongoing product to capitalize on the huge enterprise that is necessary in performing a horizon scan. This would require a dedication of resources to update, maintain, and make available the database.

#### Horizon scan conclusions

In summary, the study publications on invasive interventions for lower extremity PAD are heavily weighted toward single arm (noncomparative) studies of PTA and bypass surgery. Among the comparative studies, most evaluated comparisons between different bypass techniques or different PTA interventions. Relatively few studies compare different categories of interventions. To inform clinicians, patients, and policymakers of the relative value of different techniques, the area that may be most fruitful for summarizing appears to be the comparison between PTA and stent. This comparison is what constituted the second half of our review. The horizon scan suggests that reviews of comparative studies of atherectomy or of brachytherapy are likely to be premature, given the small number of publications. It is reasonable to assume that, similar to what was found for the systematic review of stents, about two-thirds of the potentially interesting publications for other topics would not meet criteria for systematic review. There may however, be some interesting insights to be drawn from the literature of comparisons between invasive and noninvasive interventions. Most studies appear to follow patients for a reasonable period of time (at least 18 months), but there has been a disproportionate use of imaging outcomes instead of clinically meaningful outcomes. Thus, a large proportion of the evidence provides information only on the mechanical success of opening individual vessels without providing evidence of clinical benefit. As suggested by the rate of reporting in abstracts, complications due to the procedures ought to be given greater prominence also. Future systematic reviews of topics with multiple interventions, patient differences (such as anatomy of disease), and outcomes of interest could well benefit from preliminary horizon scans to help focus (or expand) topics and key questions for the subsequent systematic reviews. For example, with PAD, the limited data found on brachytherapy in the horizon scan or the range of noninvasive interventions in comparative studies could have usefully altered the questions asked and the eligibility criteria of the systematic review.

## TASC II Citation Analysis

### Key Question 2 Review and describe the studies cited in the TASC II report26 that support the recommendations regarding choice of intervention. Judge whether the cited studies adequately support the recommendations

The TASC document made recommendations for the type of interventional therapy, surgery versus endovascular, based on the extent of atherosclerotic involvement.4 The TASC anatomic categories relate to the extent of disease (length of involvement) and luminal involvement (degree of stenosis or occlusion). In general surgery was recommended for more extensive involvement – TASC C or D – while endovascular therapy was recommended for TASC A or B disease. One would expect that the studies cited as evidence supporting these recommendations would have an anatomic description of the patients treated by a specific therapy. Preferably, the outcomes measured by the studies to assess the effect of the interventions should have been clinically based. However, the cited aorto-iliac surgery studies did not describe the preoperative anatomy and no clinically relevant outcomes were reported. The majority of studies cited for the endovascular treatment of the aorto-iliac segment did have anatomic descriptions of the studied patients, but none used the TASC classification. Most of these studies did report on clinical outcomes.

Similarly, studies cited for recommending endovascular treatment of femoral popliteal disease mostly did not provide anatomic descriptions of the involved segment sufficiently adequate to categorize by TASC classification. Clinically relevant outcomes, however, were employed in almost all of the studies. However, it was striking that only a minority of the relevant evidence for endovascular treatment of PAD was cited by the TASC II report, as compared to our systematic review of the stent literature.

The TASC II report did not fully describe their methods for reviewing or incorporating the evidence into the guideline statements. They stated only that “the Working Group reviewed the literature.”4 They used a 1993 AHRQ guideline on acute pain management to grade the recommendations.121 This system accounts for the presence of RCTs or other well-conducted clinical studies. It is not clear whether the Working Group used a systematic review approach or if they used a systematic approach to incorporate the evidence known to them into the grades. It is apparent from this review that expert opinion from the TASC participants supplemented the literature citations relating therapeutic recommendations to TASC anatomic classification. It is notable that specific formal recommendations were not made regarding the choice of surgery or endovascular treatment and that all the recommendations about choice of intervention were graded C “based on evidence obtained from expert committee reports or opinions and/or clinical experiences of respected authorities (i.e., no applicable studies of good quality).”

## Systematic Review of TASC Analyses

### Key Question 3 Perform a systematic review across invasive vascular interventions for infrarenal PAD for the association between the TASC I or II classification schemes and rates of clinical outcomes (mortality, amputation, clinical stage, reinterventions, and quality of life) after the intervention, accounting for differences in anatomy and interventions

The TASC classification scheme is a prognostic indicator that also intends to provide guidance on treatment planning. We therefore performed a systematic appraisal of how different TASC grades are associated with clinical outcomes (testing its value as a prognostic indicator), as well as how bypass and PTA compare among patients who have lesions of the same TASC grade (testing its value as a guide to treatment).

It is notable that the majority (85 percent) of 399 papers that evaluated clinical outcomes for invasive vascular procedures that were published after the first TASC report (i.e., 2001) did not report TASC classifications. This is indicative of the small uptake of TASC in clinical research over 7 years since its introduction. Since 2005, the percentage of studies that reported clinical outcomes for patients within specific TASC classifications remains low at 16 percent. It is therefore not surprising that the TASC classification does not have an extensive direct support from clinical data and empirical research.

Only 11 studies reported data providing direct comparisons (among patients included in the same study) of clinical outcomes among TASC grades or between bypass and PTA for a specific TASC grade, and only six reported relevant statistical analyses. These studies tended to be underpowered to detect statistically significant differences across TASC classifications, largely because of small numbers of patients within specific TASC levels. Nevertheless, among direct comparisons across interventions, arteries, and outcomes, there was the common trend that patients with higher levels of disease (more extensive atherosclerotic involvement) had worse clinical outcomes.

We also performed overall graphical analyses of the frequency of clinical events per intervention, artery and TASC subgroup across all studies with available evidence. We provide an overall snapshot of the frequency of clinical events across interventions, TASC grades and arteries. Again, as in the case of direct data, we observed a common trend that poor clinical outcomes occurred more frequently with worsening TASC categories. To some extent, these observations lend support to the face validity of TASC as a predictive classification scheme. However, this body of studies did not provide evidence that any specific treatment resulted in better clinical outcomes for patients in a specific TASC classification.

The majority of the data came from single cohorts of patients where no direct comparisons were reported between interventions or among TASC grades. There were numerous confounding factors related to differing baseline characteristics, eligibility criteria, and treatment thresholds across the studies. Therefore, the current evidence should not be used to draw definitive conclusions on the relative effectiveness of different interventions across arteries or TASC categories. Future analyses of larger studies are needed, focusing on the clinical significance of a TASC classification as it pertains to expected clinical outcomes and to choice of intervention.

## Systematic Review of Stent Studies

### Key Question 4 Perform systematic review of the relative safety and effect of peripheral artery stenting with other invasive vascular procedures for occlusive PAD of infrarenal vessels. Also evaluate comparisons of different stents and/or different procedures with stents

In keeping with our philosophy regarding imaging versus clinical outcomes, this review emphasized the reporting of meaningful and objective clinical outcomes, such as changes in clinical stages of the patients after intervention, walking distance, rate of amputation, rate of reinterventions, complications,- and mortality. We did not evaluate the reporting of primary or secondary patency, commonly used surrogates to gauge clinical success.

Given the large number of possible differences in the manifestations of lower extremity PAD and the large number of different specific interventions possible, there are few comparative studies covering this topic. There are only 10 RCTs comparing PTA to stent that analyzed a total of 1190 patients, with a median of 78 patients per trial. Only one study each compared three other sets of interventions.

Lower extremity PAD mostly affects people in their 60s or older. It was not surprising therefore, to find that the average age of patients in most studies was mid-60s or greater. From this perspective, then, the trials and other comparative studies are moderately to highly applicable to the Medicare population. Many of the studies, though, implicitly or explicitly excluded patients with kidney disease, and therefore on dialysis as well. All the studies were conducted in the US or other western, developed countries, though the racial or ethnic makeup of the patients was rarely reported. As was also found in the horizon scan, the large majority of these studies evaluated patients with femoral popliteal disease alone, even though review of the nonrandomized and noncomparative studies of PAD interventions in general suggests that a large percentage of patients have interventions in multiple arteries.

These trials included patients with either femoral popliteal, superficial femoral artery alone, aorto-iliac, iliac alone, or tibial disease. They included a very wide range in percent of patients with critical limb ischemia (almost the complete range from 0 to 100 percent) and a wide range of patients with cardiovascular risk factors or concomitant cardiac disease. The older trials of balloon expanded stents included only patients with relatively short vascular lesions (e.g., <5 cm). The studies used a variety of stent types, including bare, covered, or treated; and balloon-expandable or self-expanding. Importantly, it is evident that angioplasty and stent technologies continue to change rapidly. Therefore, only a minority of the available evidence are directly applicable to contemporary clinical practice. Though we have evaluated the range of stents that have been researched, several of the stents may have limited applicability in the US, such as the Palmaz stents used by several of the RCTs and the Wallstents and Strecker stents used in other trials. While it may be inevitable, and in many situations appropriate, that the field advances ahead of the publication of definitive evidence, it should be recognized that the evidence for any specific intervention technique for any specific artery segment or severity of disease is sparse at best.

The studies also varied widely in their use of stenting as a secondary intervention in their PTA arms; one of the larger, better quality trials had a crossover rate of 43 percent. Thus, we found that for each outcome of interest, very few trials, with few patients total, examined sufficiently similar patients with sufficiently similar interventions to allow for confident determinations as to the relative values of the interventions. Despite these limitations, we took the approach of performing metaanalyses (or at least drawing forest plots) for outcomes when feasible and clinically meaningful. Our aim was to use these analyses to form hypotheses about which patients may most benefit from which specific interventions. Unfortunately, as we discuss below, this goal is not yet achievable given the limitations of the data.

Other than the clinical heterogeneity of the studies, the principal limitation of the studies for most outcomes was that too few patients were analyzed, possibly for too short of a duration. This resulted in very small numbers of event rates for most clinical outcomes. The likely reason for this is that most, if not all, investigators designed their studies with imaging success (i.e., patency and/or restenosis) as the primary outcome. The result of this is that for many outcomes fewer than 2 patients in either arm, and often zero, had outcomes of interest. The statistical tools available to analyze these data are generally weak and the levels of uncertainty about any estimate are poor. For this reason, we were forced to use risk difference as the outcome measure, since it can most reliably handle no events in one arm and can provide a meaningful estimate where there are no events in either arm (namely 0), although it does not provide a reliable estimate of the confidence interval. However, summarizing risk differences across studies, particularly with metaanalysis, is problematic, since a particular risk difference must be interpreted in light of a particular underlying risk of the event (the rate in the control arm, control rate). While odds ratios and relative risks are generally stable over a range of control rates across studies, risk differences tend to change considerably with different control rates. However, despite these caveats, we found that trial results were generally statistically homogeneous (similar) for risk difference or odds ratio even given the clinical heterogeneity of the studies and a range of control rates. Despite the general statistical homogeneity, our conclusions about the summary estimates of relative rates must remain weak, given the great limitations of the analyses and the clinical heterogeneity of the studies.

Individual trials (and other studies) did find statistically significantly better clinical outcomes with one intervention or the other, but overall, the trials and other comparative studies failed to provide adequate data to show that any one intervention is superior for any outcome over any other intervention in any group of patients. However, for the most part, the data cannot be said to convincingly show that stent and PTA (or the other comparisons) are equivalent. The studies are clinically too heterogeneous and both individually and collectively too small to accurately estimate relative differences in clinical event rates.

Notably, the ACC/AHA guidelines document commented on the lack of difference between PTA and stenting for femoral popliteal lesions and was based on many of the RCTs presented in the current analysis with the exception of the recently published Krankenberg 2007. The group did suggest that stenting may have a higher technical success rate and may help salvage an immediate failure of a PTA. They did conclude that there has been an improved technical success rate with stents, their advantage in salvaging immediate PTA failures or correcting arterial stenosis after PTA.

Clinical status was measured with a wide range of metrics, with little uniformity, though most studies that reported changes in clinical status did report a measure related to the SVS (Rutherford) categories. While most of the trials did report clinical status, greater consistency in metrics would have been of greater value to compare and summarize the studies and to inform patients and clinicians. The studies mostly found no difference in clinical status regardless of planned (primary) intervention. The principal exception was one good quality, medium applicability trial (Becquemin 2003^93^), which found that patients assigned to stent had significantly worse clinical status during 4 years of followup. As described in the Results section (Miscellaneous), this trial came to the unique conclusion that overall for femoral popliteal disease, primary stent patients with Palmaz stents had worse clinical (and imaging) outcomes than primary PTA (with 13 percent crossover) patients. It is unclear why the patients in this trial faired differently from those in similar trials, though the investigators did describe that intra-stent hyperplasia was responsible for most failures. Across studies, about three-quarters of patients reported clinical improvement compared to baseline at 1 and 2 years, about two-thirds at 4 years, but (in one trial56) only about one-third of patients maintained clinical improvement by 6 to 8 years. At 1 or 2 years, critical limb ischemia occurred between 0 and about 7 percent of patients, though it affected 16 percent of patients at 6 to 8 years.

There is no evidence for differences in major or minor amputation rates between interventions, though the estimates are very uncertain and even large effects favoring either intervention cannot be excluded. In addition, the patients included in the studies mostly did not have chronic limb ischemia and therefore were not at substantial risk of amputation. Only 4 RCTs and one other study evaluated this outcome for PTA versus stent. About half the studies reported rates of reinterventions, including repeat PTA or stent placement, or bypass surgery, at least 6 months after the initial procedure. As with amputations, no difference was found between interventions but large effects cannot be excluded. Across 5 RCTs, there was no significant difference in all-cause mortality rates, with a wide confidence interval (a risk difference of about 3 to 4 percent around zero).

Only 3 RCTs measured treadmill walking distance, though each used a different specific measure. One trial of patients with superficial femoral artery disease found a statistically significant increase in walking distance after stent at 12, but not 24 months. The other two trials found no difference. The evidence regarding the relative effect of stenting on ankle-brachial index (ABI) is heterogeneous, with some studies finding a significantly greater improvement after stent placement than PTA alone, but overall, the studies mostly suggest no difference in ABI at followup, regardless of intervention; however, transient improvement after stent placement for superficial femoral artery lesions is possible. Of note, among the outcomes evaluated, ABI is the one outcome that is imperceptible to the patient and that may be only a poor surrogate outcome for true clinical outcomes.

Quality of life was investigated by only one trial of primary Palmaz stenting and primary PTA with secondary stenting in 43 percent of patients. At 1, 2, and 5 years, health-related quality of life improved equally for both groups of patients across quality of life domains.

Five studies (3 RCTs) evaluated either stent versus bypass, drug-eluting versus bare stent, or stent with and without brachytherapy. No significant differences in clinical outcomes were found for stent versus bypass or bare versus drug-eluting stents, with the exception of a significant improvement in ABI 6 months after stent, in a small unadjusted nonrandomized study. No significant difference in clinical outcomes was reported in one small trial of brachytherapy.

Overall, across studies, only two provided analyses of risk factors for poor clinical outcomes. Both an RCT and a retrospective study of stent versus PTA (or selective stenting) for iliac disease performed multivariable analyses. The trial evaluated reinterventions and the retrospective study evaluated clinical failure. Both had found no difference between the interventions, so these were not included in the regression. Only clinical severity of disease predicted poor clinical outcomes in both studies (though as a trend only in the trial). The two studies came to opposite conclusions about which sex was at higher risk of a poor outcome, but both agreed that the classic cardiovascular risk factors failed to predict poor clinical outcomes. Importantly, no study evaluated whether any one intervention was superior for a particular group of patients based on demographics, comorbid conditions, or PAD characteristics.

Complication rates (within 30 days) were reported in 10 of 12 RCTs, only 1 of 4 prospective nonrandomized studies, and all 8 retrospective studies. The outcomes were major and minor complications (overall), major and minor bleeding, embolic events requiring intervention, and 30-day mortality (all-cause). For all complications, no significant differences in events were reported or were evident from metaanalysis, although as with clinical outcomes, the analyses suffered from clinical heterogeneity and insufficient event rates (sample sizes) to accurately estimate rates. Overall, almost 4 percent of patients had major complications (requiring additional intervention or that had a substantial negative impact on patient health or well-being), regardless of PAD intervention. Less than 2 percent of patients had major postprocedural bleeding (requiring transfusion or an intervention to halt the bleeding). About 3 percent of patients had an embolic event related to the invasive intervention. Thirty-day mortality was rare; perioperatively, none of about 400 patients assigned to stent died, 2 of about 400 patients assigned to PTA died, and 1 of 54 patients who had bypass died.

In summary, despite a large volume of literature that has evaluated interventions for PAD, including 10 RCTs that directly compare primary stenting with PTA (or selective stenting), there is little definitive evidence of the relative benefits or harms of the different invasive interventions. There is a dearth of trials of patients with either aorto-iliac or infrapopliteal disease. The newer nitinol stents were used by only three of these trials (plus one RCT of stent versus bypass and two RCTs comparing different stents). The predominant primary outcome of the trials remains patency (variously defined), which has not yet been adequately shown to be an excellent predictor of clinical outcomes. True clinical outcomes have frequently been inadequately or incompletely reported and analyzed. This is a major limitation of the quality of the clinical outcomes data for several of the trials. Examples include failure to measure the outcome (e.g., ABI) in a large percentage of patients, failure to fully define the outcome (e.g., major versus minor amputation, reintervention), and failure to adequately analyze the outcome (e.g., walking distance). Furthermore, few patients have been enrolled and analyzed in the currently available trials. Only 1190 patients have been analyzed in the 10 PTA versus stent trials, with a median of 78 patients per trial. These numbers are inadequate to measure long-term clinical outcomes, the outcomes of most interest to patients and decisionmakers.

To be able to assess the true relative value of stent placement compared to PTA, it is important that future trials analyze more clearly defined questions, use greater methodological rigor, and use appropriate clinical outcomes. This includes clearly defining what the population being analyzed is (by diseased artery, lesion morphology, and clinical severity) and what the intervention and comparator is (preferably analyzing stent to PTA, with minimal crossover, since high rates of secondary stenting make the study results difficult to interpret). The primary outcomes should be important clinical outcomes, not surrogate outcomes such as patency (or even ABI). Researchers should choose the best standardized, clinically meaningful and useful measures of outcomes, particularly for potentially subjective outcomes such as “clinical status.” Trials should be adequately powered to fully evaluate these clinical outcomes, with allowance made to capture long-term followup. And complications and other safety outcomes should be fully and actively solicited and analyzed. Until high quality trials are published that address these issues and study the patients for whom the interventions are actually being used, the value of stent placement compared to PTA for patients with PAD will remain unclear.