# Results

## 3.1 Horizon Scan

### Key Question Perform horizon scan of published literature on invasive vascular procedures for the treatment of PAD (surgical bypass grafting, angioplasty, angioplasty with stent placement, atherectomy). Categorize studies based on intervention; preoperative characteristics of PAD defined by clinical, anatomic, and hemodynamic features (based primarily on TASC II classification schemes); primary outcomes; study design; and sample size

This horizon scan focuses on studies whose abstracts or titles indicate that they may have evaluated invasive interventions for treatment of PAD. Studies are categories and enumerated. Topics beyond this field are omitted, such that not all questions pertaining to management of PAD are addressed. We did not evaluate the findings of these studies, nor judge their quality. This horizon scan, thus, does not answer questions related to benefits or harms of any intervention, except to indicate the possible size of the literature base to answer those questions.

The literature searches yielded 14,815 citations, of which 2,488 reported data on primary studies of invasive interventions for lower extremity PAD. Of these, 89 percent had available abstracts.

All studies that compared interventions (including RCTs, nonrandomized comparative studies, and case control studies) had complete data extraction (these studies are listed in Appendix C). All single arm studies published since 2001 had complete data extraction. An arbitrary sample of 589 (40 percent) of earlier single arm studies had complete data extraction; the remainder had limited data extraction. Because we were usually unable to determine whether nonrandomized studies were prospectively or retrospectively designed, we grouped all nonrandomized comparative studies together (except case control studies) and all single arm (cohort) studies together.

An Excel database with the extracted data is available upon request from the report authors. This database can be queried to find specific articles that meet any given evaluated criteria.

#### Study characteristics and demographics

(Tables 3–7)

Only 5 percent of the studies were RCTs and another 9 percent were nonrandomized comparative studies; 79 percent were single arm studies (Table 3). Six percent of the citations did not provide enough information to determine study design. Among the RCTs, case control, and nonrandomized comparative studies, 14 percent had more than 2 study arms.

Across publications, 11 percent did not have an electronic abstract available. All (seven) of the case-control studies and all systematic reviews had abstracts; 97 and 94 percent, respectively, of RCTs and comparative studies had abstracts. Similarly, 93 percent of single arm studies had abstracts. The study design of about half the publications without abstracts could not be determined; thus, 12 percent of studies without a known study design had abstracts.

RCTs and other comparative studies tended to have larger numbers of patients than single arm studies (Table 4). The relatively small sample size of the single arm studies is in part explained by a large number of descriptions of small surgical cohorts. A total of 492,679 subjects were included in the (87 percent of) studies that reported sample sizes in their abstracts; extrapolating to those studies without sample size data, almost 570,000 patients have been evaluated (although this includes double counting of patients reported in multiple publications). About 3 percent of these subjects were enrolled in RCTs. The median followup time was 18 months in RCTs, 24 months in comparative studies and single arm studies, and 60 months in the small number of case control studies (Table 5). However, determining accurate followup durations from abstracts was problematic since only selected data are reported in abstracts. Notably, the large majority of RCTs (92 percent) reported study duration, but almost 30 percent of other studies did not report duration.

Most studies did not report the years of the interventions in their abstracts (Table 6); this was particularly true among RCTs. Half of the studies that reported data began their interventions between the mid 1980s and the late 1990s. Across studies, 1 percent had interventions performed in the 1950s, 4 percent in the 1960s, 7 percent in the 1970s, 30 percent in the 1980s, 44 percent in the 1990s, and 15 percent since 2000.

The median age of participants in studies of different designs ranged from 67 to 70 years; however, we obtained age data from only about 15 percent of abstracts (Table 7).

##### Summary of study characteristics and demographics

- How many articles reported on direct comparisons of interventions (including invasive) for PAD?
  - 127 RCTs, 231 other studies
- How large were the studies of invasive interventions for PAD?
  - On average, between about 70 and 100 patients
  - ¾ of studies evaluate at least 30 patients per intervention
- How long were patients followed after their interventions?
  - Most studies followed patients for at least 18–24 months.
  - In general, fewer than ¼ of studies followed patients for less than 1 year.
- When were the invasive procedures performed?
  - Most data (¾) are from studies that began to perform the procedures more than a decade ago.
- How applicable are the studies to the Medicare population?
  - On the basis of age, most studies have fair to good applicability to the Medicare population.
  - Among studies that reported age in their abstracts, the average ages were 67 to 70 years. Fewer than ¼ of studies had mean ages below 65 years.

Table 3 Horizon scan: Study designs

Study Design | Number | Percent
Randomized controlled trial | 127 | 5
Comparative | 224 | 9
Case control | 7 | 0.2
Single arm | 1,955 | 79
Systematic review | 26 | 1
No data (unable to determine) | 151 | 6
Total | 2,488 | 100

Table 4 Horizon scan: Number of subjects

Study Design | No. Studies with Data | Sample Size | | Total | % Studies No Data | Extrapolated Total^*^
Study Design | No. Studies with Data | Median | IQR | Total | % Studies No Data | Extrapolated Total^*^
RCT | 120 | 100 | 56 – 199 | 16,788 | 6% | 17,767
Comparative | 198 | 120 | 62 – 240 | 83,239 | 12% | 94,169
Case control | 7 | 77 | 42 – 351 | 1,060 | 0% | 1,060
Single arm | 1,824 | 66 | 32 – 146 | 379,736 | 7% | 406,592
Total across studies^†^ | 2154 | | | 492,679 | 13% | 566,968

IQR, interquartile range. Details for studies with unknown study design (n=151) not included.

* Estimate of total number of subjects, including studies that did not report sample size in their abstracts.

† Including studies with unknown design.

Table 5 Horizon scan: Patient followup (months)

Study Design | No. Studies with Data | Followup^*^ (months) | | % Studies No Data
Study Design | No. Studies with Data | Median | IQR | % Studies No Data
RCT | 115 | 18 | 9 – 36 | 8%
Comparative non RCT | 158 | 24 | 12 – 40 | 29%
Case control | 5 | 60 | 33 – 69 | 28%
Single arm^†^ | 787 | 24 | 12 – 41 | 60% (26%)^‡^

IQR, interquartile range; NA, not applicable. Studies with unknown study design (n=151) not analyzed

* Either average (mean or median) or maximum, as reported by authors

† Data from all studies published since 2001, but only arbitrary sample of earlier studies.

‡ Percent for which no data were available for analysis (percent of studies with full data extraction [n=1,056] with no data reported in title or abstract).

Table 6 Horizon scan: Year in which the interventions started

Study Design | No. Studies | Start Year | | % Studies No Data
Study Design | No. Studies | Median | IQR | % Studies No Data
RCT | 22 | 1994 | 1983 – 1997 | 83%
Comparative non RCT | 74 | 1988 | 1985 – 1996 | 67%
Case control | 2 | 1982, 1996 | | 71%
Single arm^*^ | 335 | 1992 | 1986 – 1998 | 68%

Studies with unknown study design (n=151) not analyzed

* Data from all studies published since 2001, but only arbitrary sample of earlier studies.

Table 7 Horizon scan: Subject age (years)

Study Design | No. Studies with Data | Study Average Age | | % Studies No Data
Study Design | No. Studies with Data | Median | IQR | % Studies No Data
RCT | 19 | 70 | 67 – 72 | 85%
Comparative non RCT | 36 | 67 | 63 – 70 | 84%
Case control | 1 | 69 | -- | 86%
Single arm^*^ | 241 | 67 | 63 – 70 | 88% (77%)^†^

IQR, interquartile range. Studies with unknown study design (n=151) not analyzed

* Data from all studies published since 2001, but only arbitrary sample of earlier studies.

† Percent for which no data were available for analysis (percent of studies with full data extraction [n=1,056] with no data reported in title or abstract).

#### PAD characteristics

(Tables 8–10)

Across reviewed studies, 85 percent of the abstracts provided sufficient information to determine which arteries were treated (Table 8). RCTs tended to be conducted in patients with either femoral popliteal disease alone (67 percent) or combination artery disease (20 percent), which usually included the femoral popliteal artery. In contrast, nonrandomized comparative and single arm studies were more likely to be conducted in patients with mixed disease, with only about a third of studies evaluating femoral popliteal disease exclusively.

Our estimates of the maximum severity of PAD symptoms (Table 9) were necessarily limited. There was a great degree of heterogeneity in the ways that abstracts described the severity of disease. In many, if not most, cases we had to extrapolate the qualitative descriptions of patients into the SVS scale. Furthermore, our aim was to capture the most severe level of disease included in the studies, though this was not always clear. Ideally it would have been better to capture the average and range of disease severity in the studies, but this approach was not feasible from review of the abstracts. The distinction between minor and major tissue loss was particularly difficult to ascertain from the abstracts, so these categories have been merged. Furthermore, over half the studies did not report adequate data in their abstracts to assess disease severity. RCTs were more likely to include patients who had only claudication and correspondingly less likely to include patients with rest pain or tissue necrosis. Nonrandomized comparative studies were about equally likely to include patients with different levels of PAD severity as single arm studies. Overall, about 15 percent of studies were restricted to patients with claudication (but almost 40 percent of RCTs), about one-quarter included patients with rest pain or claudication, and almost two-thirds included patients with tissue loss (but only about 40 percent of RCTs). Only 41 studies (2.7 percent) reported the patients’ TASC classification in the abstract (Table 10); the large majority of these included patients with TASC D disease. Note that studies that provided data on clinical outcomes for patients with specific TASC grades are analyzed in Question 2.

##### Summary of PAD characteristics

- Which arteries have been evaluated for invasive procedures?
  - About 1/3 of studies evaluated patients with femoral popliteal disease and ½ with disease in multiple arteries, usually including femoral popliteal arteries.
  - About 15 percent had aorto-iliac disease alone and only about 2 percent had tibial disease alone.
- What was the severity of PAD symptoms among patients in studies of invasive procedures?
  - A complete answer to this question is not possible without evaluating the full text of the articles.
  - Among those studies that reported some relevant data in their abstracts, about 60 percent included patients with tissue loss, about 25 percent included patients with rest pain but not tissue loss, and about 15 percent included patients with claudication only.
  - RCTs more commonly included patients with only claudication.
- What was the TASC classification of patients in studies of invasive procedures?
  - Only 3 percent of studies reported TASC classification in their abstracts.
  - Most of these studies included patients with more severe disease (grade C or D); only 10 percent included only patients with grade A or B.

Table 8 Horizon scan: Arteries evaluated, N (%, per study design)

Study Design | No. Studies with Data | Aortoiliac | Femoral popliteal | Tibial | Combination | % Studies No Data
RCT | 115 | 13 (11%) | 77 (67%) | 2 (2%) | 23 (20%) | 10%
Comparative non RCT | 194 | 34 (18%) | 67 (35%) | 2 (1%) | 91 (47%) | 13%
Case control | 4 | 1 (25%) | 1 (25%) | 0 (0%) | 2 (50%) | 43%
Single arm^*^ | 894 | 151 (17%) | 262 (29%) | 17 (2%) | 464 (52%) | 15%
Total^†^ | 1,207 | 199 (16%) | 407 (34%) | 21 (2%) | 580 (48%) | 15%

Details for studies with unknown study design (n=151) not included.

* Including only studies published since 2001 and an arbitrary sample of earlier studies

† Including studies with unknown design.

Table 9 Horizon scan: Maximum severity of PAD symptoms, N (%, per study design)

Study Design | No. Studies with Data | Mild | Moderate Claudication | Severe | Rest Pain | Tissue Loss | % Studies No Data
RCT | 54 | 0 (0) | 10 (19) | 10 (19) | 13 (24) | 21 (39) | 58%
Comparative non RCT | 82 | 0 (0) | 8 (10) | 8 (10) | 12 (15) | 54 (66) | 63%
Case control | 1 | 0 (0) | 0 (0) | 0 (0) | 1 (100) | 0 (0) | 86%
Single arm^*^ | 495 | 3 (0.6) | 32 (6) | 21 (4) | 126 (25) | 313 (63) | 53%
Total^†^ | 640 | 3 (0.5) | 51 (8) | 40 (6) | 154 (24) | 392 (61) | 58%

IQR, interquartile range. Details for studies with unknown study design (n=151) not included.

* Including only studies published since 2001 and an arbitrary sample of earlier studies

† Including studies with unknown design.

Table 10 Horizon scan: TASC classification

TASC classification | No. Studies^*^ | Percent Studies
TASC classification | No. Studies^*^ | Total | With Data
A | 1 | 0.1% | 2%
B | 3 | 0.2% | 7%
C | 10 | 0.7% | 24%
D | 27 | 2% | 66%
No Data | 1,466 | 97% | --

* Data from all studies published since 2001, but only arbitrary sample of earlier studies.

#### Characteristics of the interventions

(Tables 11–15)

Overall (among all abstracts, including all single arm studies regardless of publication date), almost half the studies reported on surgical bypass, about 40 percent on PTA, about one-sixth on stent, and one-ninth on atherectomy (Table 11). About one-quarter of RCTs evaluated stent, one-half PTA, and one-half bypass. Among the RCTs, 67 percent compared the same type of intervention to itself (e.g., one surgery versus another surgery); only one-third compared different types of interventions (e.g., PTA versus stent); two studies compared three different types of interventions. Similarly, among the nonrandomized comparative studies, 60 percent compared one type of intervention to itself, 32 percent compared two types of interventions, and 8 percent compared three types of interventions. Table 12 displays the number of RCTs and comparative studies (and the numbers of reported patients) that compared types of interventions (and the single arm studies evaluating each intervention). The most common comparison was between different types of bypass surgery (40 RCTs and 87 comparative studies). About 20 RCTs each compared different types of PTA or PTA and stent; between about 20 and 40 comparative studies compared PTA to itself, PTA to stent, or PTA to bypass. In addition about 20 comparative studies compared bypass and atherectomy. Other comparisons were relatively rare.

Notably, at the level of the horizon scan, 30 RCTs and 51 comparative studies compared stent to another intervention (or another stent). This is in contrast with the studies that met criteria for the systematic review (below), where 12 unique RCTs met criteria and 14 comparative studies met criteria. The difference in the numbers of eligible studies is due to duplicate publications, foreign language publications, lack of reporting of data comparing stent to an alternative intervention, lack of clinical outcomes, and other reasons.

Noninvasive (medical) therapy was compared to invasive interventions in 21 studies (Table 13). Single arm studies of noninvasive therapies were excluded from the horizon scan. Most of the abstracts did not describe the specific interventions used. Brachytherapy was described in 34 abstracts (Table 14). Interestingly, the majority of the studies reporting brachytherapy were RCTs, with only one comparative or case control study. Various other interventions were reported in abstracts that did not clearly fall into one of the intervention categories we evaluated (Table 15). We included laser angioplasty in this group, although these studies were also categorized as PTA studies. We also included abstracts that did not adequately describe the interventions used (e.g., “revascularization”).

##### Summary of intervention characteristics

- What invasive interventions for PAD have been studied?
  - Almost ½ of studies evaluated surgical bypass; about 40 percent evaluated PTA.
  - We found 1,191 studies of bypass, 1,021 studies of PTA, 408 studies of stenting, and 271 studies of atherectomy.
  - Among comparative studies, almost 2/3 evaluated bypass and almost ½ evaluated PTA; 71 comparative studies evaluated stenting and 34 evaluated atherectomy.
- What interventions have been compared for the treatment of PAD (among studies that included an invasive intervention)?
  - The most common comparisons have been between different surgical bypasses (40 articles of RCTs and 87 other studies), followed by PTA versus stent (23 articles of RCTs and 34 other studies), PTA versus bypass (7 articles of RCTs and 39 other studies), and PTA versus PTA (19 articles of RCTs and 18 other studies).
  - Other comparisons appear in fewer than about 20 articles each.
- How many studies compared medical treatments to invasive interventions for PAD?
  - We found 21 studies that evaluated a range of interventions including usual care, anticoagulants, exercise, fibrinolysis, and others.
- How many studies have evaluated brachytherapy for PAD?
  - We found 34 articles that used brachytherapy in conjunction with invasive interventions for PAD.
  - 20 of these were comparative studies; there is 1 systematic review on the topic.
- What other interventions have been evaluated for PAD?
  - We found a wide range of interventions among the applicable articles (in addition to bypass, PTA, stenting, and atherectomy) including laser angioplasty, fibrinolysis or thrombolysis, endarterectomy, thrombectomy or embolectomy, amputation, cryoplasty, and others.

Table 11 Horizon scan: Interventions evaluated, N (%, per study design^*^)

Study Design | No. Studies | PTA | Stent | Bypass | Atherectomy
RCT | 127 | 67 (53%) | 30 (24%) | 58 (46%) | 7 (6%)
Comparative non RCT | 224 | 89 (40%) | 39 (17%) | 163 (73%) | 25 (11%)
Case control | 7 | 4 (57%) | 1 (14%) | 3 (43%) | 2 (29%)
Single arm | 1,953 | 829 (42%) | 322 (16%) | 897 (46%) | 213 (11%)
Systematic review | 26 | 11 (42%) | 5 (19%) | 14 (54%) | 1 (4%)
Total^†^ | 2462 | 1,021 (41%) | 408 (17%) | 1,191 (48%) | 271 (11%)

Details for studies with unknown study design (n=151) not included.

* Add to more than 100% because studies with multiple interventions (used in different or the same individuals) are double-counted.

† Including studies with unknown design; not including systematic reviews.

Table 12 Horizon scan: Treatment comparisons by study design (Total number of subjects evaluated)^*^

Study Design | | PTA | Stents | Bypass | Atherectomy | Medical | Single Arm Studies
PTA | RCT | 19 (1312) | 23 (3030) | 7 (982) | 6 (234) | 7 (630) | 828 (169,299)
PTA | Comparative^†^ | 18 (2988) | 34 (4379) | 39 (40,097) | 7 (1793) | 9 (1832) | 828 (169,299)
Stents | RCT | | 6 (467) | 1 (86) | 0 | 0 | 323 (89,109)
Stents | Comparative^†^ | | 4 (304) | 9 (1222) | 2 (320) | 2 (475) | 323 (89,109)
Bypass | RCT | | | 40 (7216) | 2 (no data) | 0 | 898 (211,521)
Bypass | Comparative^†^ | | | 87 (28,657) | 19 (4634) | 10 (1804) | 898 (211,521)
Atherectomy | RCT | | | | 0 | 0 | 213 (25,028)
Atherectomy | Comparative^†^ | | | | 3 (403) | 2 (174) | 213 (25,028)

* Ignores abstracts with no data on sample size. Double counting of articles and subjects occurs if 3 or more intervention types are evaluated.

† Comparative includes comparative nonrandomized studies and case control studies.

Table 13 Horizon scan: Medical treatments compared to invasive interventions

Medical Treatment | No. Studies
Angiography | 3
Aspirin and advice on smoking and exercise | 2
Best medical therapy and exercise | 1
Conservative treatment | 5
Fibrinolysis | 2
Medical therapy | 3
Physical training / Exercise | 3
Probucol | 1
Prostanoids and/or antibiotics | 1
Total | 21

Table 14 Horizon scan: Brachytherapy, N and %, per study design

Study Design | No. Studies | Percent of Studies
RCT | 19 | 15%
Comparative non RCT | 1 | 0.4%
Case control | 0 | 0%
Single arm | 16 | 0.8%
Systematic review | 1 | 4%
Total^*^ | 34 | 1.4%

Details for studies with unknown study design (n=151) not included.

* Including studies with unknown design; not including systematic reviews.

Table 15 Horizon scan: Other interventions evaluated

Intervention | No. Studies
Laser angioplasty^*^ | 139
Fibrinolysis / Thrombolysis | 27
Undefined revascularization procedures | 13
Endarterectomy | 10
Thrombectomy/Embolectomy | 7
Amputation | 7
Cryoplasty | 6
Arteriovenous fistula | 5
Laser recanalization | 5
Extraluminal recanalization | 4
Lumbar sympathectomy | 3
Osteotrepanation | 2
Gene therapy | 1

* Also coded as PTA in horizon scan

#### Outcomes

(Tables 16 & 17)

About 80 percent of the evaluated abstracts reported data on which outcomes were evaluated (Table 16). From our experience comparing full text articles to abstracts, we believe it is likely that the percentage of abstracts reporting specific outcomes underestimate the true number of articles that report the outcomes. It is common to report only statistically significant or “interesting” outcomes in the abstracts. That said, imaging success was the most frequently reported outcome across study designs (69 percent) and was particularly common among RCTs (84 percent), but fewer than half the systematic reviews evaluated imaging success (our systematic review agrees with the majority and does not). The distribution of other reported outcomes was fairly similar across study designs. Complications, mortality, amputations, and hemodynamic success were reported in approximately one-third of abstracts, symptomatic relief and reinterventions were reported in about one-fifth, and quality of life and economic evaluations were rarely reported. Overall, 38 percent of studies reported clinical outcomes in their abstracts. However, three-quarters of the comparative studies reported clinical outcomes (Table 17).

In addition, 28 percent of abstracts (434 of 1510) reported an evaluation of risk factors or predictors of response to treatment, and 42 percent of RCTs (67 of 359) and 58 percent of comparative studies (93 of 359 studies) reported statistically significant differences between interventions.

##### Summary of outcomes

- What outcomes have been reported among (abstracts of) studies of invasive interventions for PAD?
  - Imaging success was the most commonly reported outcome, among almost 70 percent of studies. Imaging success was more commonly reported among RCTs (84 percent), but less commonly among systematic reviews (42 percent)
  - Clinical outcomes (and hemodynamic success) were reported less frequently. About 40 percent of studies, overall, reported clinical outcomes in their abstracts. About 75 percent of comparative studies, though, reported clinical outcomes.
  - Complications, mortality, amputations, and hemodynamic success were reported in about 1/3 of study abstracts each, across study designs, except that hemodynamic success was included in only 15 percent of systematic reviews.
  - Symptomatic relief and reinterventions were reported in about 20 percent of abstracts.
  - Quality of life and economic evaluations were reported in few studies (<5 percent).

Table 16 Horizon scan: Outcomes reported, excluding studies with no outcome data reported in abstracts, N (%, per study design^*^)

Outcome | All Studies^†^ | RCT | Compar- ative | Case Control | Single Arm^‡^ | Systematic Review
Imaging success | 928 (69%) | 103 (84%) | 140 (68%) | 5 (71%) | 679 (69%) | 11 (42%)
Complications | 499 (37%) | 38 (31%) | 65 (31%) | 2 (29%) | 393 (40%) | 6 (23%)
Mortality | 462 (34%) | 30 (24%) | 81 (39%) | 1 (14%) | 348 (35%) | 9 (35%)
Amputation | 449 (33%) | 28 (23%) | 82 (40%) | 1 (14%) | 338 (34%) | 9 (35%)
Hemodynamic success | 386 (29%) | 42 (34%) | 44 (21%) | 1 (14%) | 299 (30%) | 4 (15%)
Symptomatic relief | 290 (22%) | 28 (23%) | 39 (19%) | 1 (14%) | 222 (22%) | 3 (12%)
Reintervention | 267 (20%) | 22 (18%) | 30 (14%) | 1 (14%) | 213 (22%) | 3 (12%)
Quality of life | 52 (4%) | 6 (5%) | 15 (7%) | 0 | 31 (3%) | 3 (12%)
Economic evaluation | 26 (2%) | 3 (2%) | 11 (5%) | 1 (14%) | 10 (1%) | 0
No. Studies | 1,342 | 123 | 207 | 7 | 990 | 26

Details for studies with unknown study design (n=151) not included.

* Add to more than 100% because studies with multiple interventions double-counted.

† Including studies with unknown design, but not including systematic reviews)

‡ For single arm studies, data from all studies published since 2001, but only arbitrary sample of earlier studies.

Table 17 Horizon scan: Treatment comparisons of studies with clinical outcomes^*^

Study Design | | PTA | Stents | Bypass | Atherectomy | Medical | Single Arm Studies^‡^
PTA | RCT | 5 | 13 | 4 | 2 | 5 | 269
PTA | Comparative^†^ | 10 | 17 | 21 | 3 | 4 | 269
Stents | RCT | | 4 | 1 | 0 | 0 | 143
Stents | Comparative^†^ | | 3 | 5 | 0 | 0 | 143
Bypass | RCT | | | 31 | 0 | 0 | 278
Bypass | Comparative^†^ | | | 57 | 7 | 7 | 278
Atherectomy | RCT | | | | 0 | 0 | 83
Atherectomy | Comparative^†^ | | | | 0 | 2 | 83

* Double counting of articles and subjects occurs if 3 or more intervention types are evaluated.

† Comparative includes comparative nonrandomized studies and case control studies.

‡ Since 2001.

#### Change in studies overtime

(Figures 1–3)

Figure 1 illustrates the number of studies published over time, according to research design. As commented above, the vast majority of the published studies are noncomparative. The increase in the number of publications around the late 1980s to early 1990s coincides with the introduction of widespread use of PTA for peripheral vascular disease (Figure 2). Studies on stents have increasingly been published since the early 1990s. Figure 3 shows the breakdown over time per type of artery. The analysis is restricted to only comparative studies because artery type was not extracted from all single arm studies before 2001. Similar increases in publications over time are seen for studies of interventions in all artery types.

##### Summary of time

- How have studies evaluating invasive interventions for PAD changed over time?
  - The exponential growth in single-arm studies stopped in about 1990, after which about 80 relevant articles have been published annually.
  - The growth of RCTs and other comparative studies continue to rise steadily since the 1970s. About 20–30 comparative studies a year are currently published.
  - Systematic reviews began to be published in the mid-1990s and are more common since about 2000.
  - Single arm studies of PTA peaked in about 1990 at about 50 articles; currently about 30 such articles are published annually. Single arm studies of bypass have steadily become more common; currently about 30 such articles are published annually. Single arm studies of stents have grown rapidly since the late 1980s; currently about 25 such articles are published annually.
  - The growth of comparative studies has generally matched those of single arm studies. Comparative studies of PTA or bypass are most common (about 10 per year currently). Comparative studies of stents are growing at a faster rate, but currently about 7 such articles are published annually.
  - Since about 1990, the proportion of studies evaluating the different arteries has remained fairly constant. Studies evaluating femoral popliteal arteries and studies evaluating a combination of arteries each are about twice as common as studies evaluating aorto-iliac arteries. Studies exclusively of tibial arteries are relatively rare.

Figure 1 Evolution of the number of published studies overtime per research design

Simple graph of publication year versus number of publications, by type. Four lines represent the annual number of publications for RCTs, nonrandomized comparative studies, single arm studies and systematic reviews from the mid 1960s until 2006. The large majority of the publications are single arm noncomparative studies. In decreasing order, nonrandomized comparative studies, RCTs and systematic reviews have been published in smaller number and in later years.

Figure 2 Evolution of the number of published studies over time per intervention

Simple graphs of publication year versus number of publications, by type. The figure has 2 panels, one for single arm studies and one for comparative studies (including RCTs). In each panel, four lines represent the annual number of publications for PTA without stents, Stents, bypass surgery and atherectomy from the mid 1960s through 2006. In both panels increasing number of papers have appeared in the literature for all intervention types, perhaps with the exception of atherectomy (for which the line shows small if any increase).

Figure 3 Evolution of the number of published studies over time per artery (comparative studies)

Simple graph of publication year versus number of publications, by type. Four lines represent the annual number of publications for aortoiliac, femoral popliteal, tibial or a combination of these arteries from the mid 1960s until 2006. The majority of the publications dealt with the treatment of femoral popliteal disease. In decreasing order of annual publications, papers studied a combination of arteries, aortoiliac disease anf finally, tibial disease (a minority of publications).

## 3.2 TASC II Citation Analysis

The TASC consensus document26 was a result of collaboration by leading authorities in the area of PAD, which led to recommendations for both the surgical and endovascular management of PAD. These recommendations are based on the anatomic extent and severity of atherosclerosis, but the medical risk of the individual patient also influences the approach. Evidence from the literature is cited to support the management of each TASC Classification (A, B, C, D). Our review provides a brief synopsis of the studies that were cited as evidence for a specific approach, an analysis of the strength of the evidence for each of the TASC recommendations, and a detailed examination of the anatomic descriptions of the atherosclerotic process in each of the studies.

The studies cited in the TASC 2007 document upon which the recommendations for surgery or endovascular treatment of aorto-iliac disease, and for surgery or endovascular treatment of femoral popliteal disease were based are reviewed in that order. Since the studies for surgery of the femoral popliteal segment only compared the types of graft material used for femoral popliteal bypass, they are not included. Only studies that compared surgery to endovascular treatment of that anatomic segment are included.

### Aorto-iliac disease

#### Comparison of surgery and endovascular treatment

TASC II did not cite any such comparative studies.

#### Surgery

(Table 18)

The TASC II document relied on two studies as evidence for advocating aortofemoral surgery for “diffuse” disease or total occlusion. Reed 2003 summarizes the results of a retrospective review of 281 patients compiled in a vascular registry from 1980 to 1999.^50^ This single institution case series provides no data on the patients’ preoperative clinical state, other than a simple classification into claudication and limb salvage (59 percent had claudication). The major focus of this paper was to determine the effect of age on the results of aortobifemoral surgery as assessed by 5-year cumulative patency rates. No anatomic descriptions of the disease type and extent were given. The preponderance of patients received Dacron grafts. All distal anastomoses were at the femoral artery level. Overall, the 5-year primary patency rates averaged 85 percent and 5-year secondary patency rates 92.5 percent. The age of the patient influenced primary patency rates, such that younger patients had poorer patency rates. Other outcome measures, such as clinical improvement, hemodynamics, and the results of imaging were not reported. They had a mortality rate of 1 percent and major morbidity rate of 9 percent.

The TASC II document also cited a systematic review (de Vries 1997) of aorto-iliac/femoral bypasses published between 1970 and 1996.^51^ The metaanalysis included 23 case series, with over 6,000 patients. The proportion of the patients in the limb salvage category was extremely variable across studies. The patency rate for people with claudication was 91 percent at 5 years, compared to 87.5 percent for patients with ischemia. The distal anastomosis was at the iliac level in several of the studies, which is a recognized factor that can potentially reduce patency. Postoperative improvement in clinical status, hemodynamics and imaging were not reported. Mortality decreased from 4.6 percent in the older studies to 3.3 percent in the more recent studies.

Notably, the two citations refer only to cohort studies, mostly retrospective in design. In both papers, important characteristics describing the disease were not reported, including clinical classification other than claudication versus limb salvage, hemodynamics, and anatomy to allow TASC classification. Neither specifically reported TASC classification (though the systematic review was performed prior to the original classification.

Clinical, hemodynamic and imaging data were not presented in these papers. Patency was the primary outcome. While complications and the mortality rates were cited, neither the incidence of amputation nor number of reinterventions was provided. Both studies were graded to be of poor quality.

#### Endovascular treatment

(Table 19)

The evidence cited for the management of aorto-iliac disease by catheter-based techniques consists of two narrative reviews (Becker 1989, Rutherford 1992),52,53 a single center cohort (Murphy-2004),54 a metaanalysis (Bosch 1997),31 and two RCTs (the Dutch Iliac Stent Trial55–57 and Ponec 2004).58 The two reviews provided summary overviews of previous studies, but no unique data or systematic reviews. Murphy 2004 was a retrospective analysis of a more than 9-year period (1992–2001) with aorto-iliac stents. At a mean followup of 33 months 80 percent of limbs improved at least two Rutherford grades (74 percent asymptomatic), while primary patency averaged 74 percent. The mortality rate was 0.5 percent and the major morbidity rate was 7 percent, which required corrective surgery in 2 percent overall. No postoperative clinical data were presented.

The Dutch Iliac Stent Trial, a multicenter RCT, compared primary PTA with selective stent placement versus primary stent placement.55–57 This study is described in greater detail in the systematic review below (section 3.4) This well designed study included 213 patients from 1993 to 1996. The two groups were comparable at baseline and intention-to-treat analysis was employed, but no blinding was carried out. The clinical outcomes included: quality of life, improvement and maintenance of at least one Fontaine clinical classification, and improvement of the ABI of >0.10. The authors also reported patency of the treatment site, as determined by peak Duplex systolic flow velocities of <2.5. This trial concluded that PTA with selective stent placement leads to better clinical results as judged by symptomatic improvement. There was no difference between selective or primary stenting, however, with respect to quality of life, patency of the iliac artery and ABI.

The second RCT (Ponec 2004), also described in greater detail in section 3.4, compared two types of stents, the nitinol Smart stent, a memory shape alloy stent, to the Wallstent, a self expanding stainless steel stent, in an equivalency trial design trial at 20 sites.58 In patients with a suboptimal iliac artery PTA 203 patients were recruited in this multicenter trial designed to show equivalency. Approximately 42 percent in the Wallstent group and 36 percent of the patients in the Smart Stent group had claudication preoperatively. At a mean followup of 9 months, post-treatment clinical outcomes correlated with improvement from severe to moderate claudication (3.5 to 1.9 on the Rutherford scale), while an increase in ABI from 0.6 to 0.9 was maintained at 12 months by both groups. The authors concluded that the self-expanding stainless steel stent (Wallstent) had comparable outcomes to the nitinol stent, a shape memory alloy.

Bosch 1997 was a metaanalysis of six PTA cohort studies (1300 patients) and eight stent placement cohort studies (816 patients).31 The former was based on studies published from 1980, while the latter contained studies published from 1990 on. The authors encountered difficulty in applying a uniform definition of patency and used clinical angiographic and hemodynamic criteria. Thirty-three percent of the patients undergoing PTA met limb salvage criteria, in contrast with 15 percent, on average, of patients in the stent studies. The mean length of lesions undergoing PTA averaged 2.6 cm, while the lesions undergoing stent placement averaged 4.1 cm. Occlusion was present in 20 and 28 percent of segments receiving PTA and stent, respectively. Clinical improvement measures were not reported, but hemodynamic improvement was greater in the stent group than the PTA group. The authors found variability in the rate of occlusions included in each study and concluded that the long-term patency rates were better with stenting.

Of the four papers cited for endovascular treatment of aorto-iliac disease two were RCTs, but one was a systematic review of cohort studies and the fourth was a retrospective single institution cohort. Only the Dutch trial provided clinical classification in a form recommended by TASC (Fontaine), while two studies merely provided the proportion of patients with claudication and limb salvage. All described the hemodynamic status of the study limbs. All provided some data on the anatomy of the lesion. The majority of the lesions were described as stenosis (average 80 percent). All four studies described the mean length of the lesion; the majority were less then 5 cm of stenosis/occlusion. None provided TASC classifications or adequate anatomic data to derive them.

The Rutherford or Fontaine classification was used to define clinical improvement in three of the studies, while the Dutch Trial also provided quality of life outcomes. All studies had hemodynamic outcomes by ABI or pulse-volume readings, as well as patency rates. Complications and mortality rates were detailed in three of the four studies, but amputation rates were not provided in any of the studies. Reintervention rates varied between 4 and 19 percent in the three studies where it was presented. The two trials were rated to be of either fair or good quality, the systematic review of fair quality, but the retrospective cohort study was of poor quality.

### Femoral popliteal disease

#### Comparison of surgery to endovascular treatments

(Table 20)

Two RCTs comparing surgery and PTA were cited by the TASC II document.59,60 Wolf 1993 reported an RCT of whether PTA was as effective as surgery for atherosclerosis involving either the aorto-iliac or femoral popliteal segments.60 Trial inclusion criteria were a greater than 80 percent diameter stenosis or a total occlusion less than 10 cm in length of the iliac or femoral popliteal segments. The patients spanned Rutherford clinical classification 2 to 5 and had an ABI less than 0.9 at rest. Thirty percent of the PTA patients required additional vascular procedures, approximately half due to treatment failure and half due to a technically successful PTA that failed to result in an adequate revascularization. Both groups evidenced a substantial and durable increase in the mean ABI. Survival and primary patency did not differ among the two treatment groups. Both groups of patients noted improvement in the Sickness Impact Profile Score following intervention.

Adam 2005 was a multicenter RCT, conducted in 27 hospitals;59 the trial assigned 452 patients with severe chronic limb ischemia and involvement of the femoral popliteal segment to either surgery first or PTA first. The trial evaluated amputation-free survival and quality of life. Five percent of patients randomized to surgery and 3 percent to PTA died within 30 days of their intervention. The immediate failure rate was 3 percent in the surgical group. By one year 44 percent of the surgical patients had clinical failure (death, major amputation or return/persistence of symptoms). By contrast, 20 percent of the 224 patients undergoing PTA were technical failures. The 1-year amputation free survival was comparable between the PTA and surgical groups, at approximately 50 percent; the 3-year rates were also comparable. However, after 2 years, surgery was associated with a statistically significant reduced risk of amputation, death or both. While morbidity was lower with PTA, immediate failure and re-intervention rate were higher than with surgery. The overall conclusion of this study was that there was no difference between the two strategies.

#### Surgery

TASC II did not cite any studies specific to surgery for femoral popliteal disease.

#### Endovascular treatment

(Table 21)

One systematic review (Muradin 2001) of observational studies and one RCT was cited regarding the comparison of PTA and stent for femoral popliteal disease.61 It included studies published from 1993 to 2000, including nine PTA studies and seven stent studies. Two studies included both PTA and stents and only one of the 19 was carried out in a randomized controlled fashion. The principal focus of the review was on patency, although clinical improvement by SVS criteria was reported in the 11 of 19 studies. The authors concluded that the results were equivalent for PTA and stent with claudication and stenosis, but PTA was inferior to stent for more severe disease.

#### Overall

In contrast with the studies cited for aorto-iliac disease, almost all the studies cited for femoral popliteal disease were RCTs. The majority of these trials gave a description of the pretreatment status of the patients with a version of the Rutherford classification, though two reported only the proportion of patients with claudication versus limb salvage. All the RCTs, but not the systematic review of cohort studies reported baseline ABIs. The two RCTs that compared surgery to PTA provided no anatomic data (including TASC classification). In the other studies, stenosis predominated over occlusion in 60 to 70 percent of patients. The lengths of the lesions were well described in these studies and the majority were around 2 cm. For most of the trials, sufficient anatomic data was available to retrospectively define the TASC anatomic category; though none explicitly provided this.

Postoperative clinical status, usually by the Rutherford classification, was available in the trials, while two studies described quality of life measures. Seven trials employed duplex scans to assess the long-term anatomic status of the intervention. Although morbidity was available in only a small number of the trials, mortality was provided in the majority. Amputation rates and reintervention was described in three of the trials. Among the trials, two were of good quality, four of fair quality, and two of poor quality; the systematic review was judged to be of poor quality.

Table 18 Characteristics of TASC II citations regarding surgery for aorto-iliac disease

Characteristic | Reed 2003^50^ | de Vries 1997^51^
Study type | Retrospective cohort | Systematic review of cohort studies
No. subjects | 281 | 6250 (23 studies)
Multicenter? | No | (Yes)
A priori sample size calculation? | No | NA
Allocation concealment? | NA | NA
Clinical classification by SVS? | No | (Claudication vs. limb salvage)
Hemodynamic classification? | No | No
TASC/Anatomic classification | No | No
Baseline comparability | NA | NA
Intention to treat analysis? | No (39% drop out) | NA
Reason for dropouts | nd | nd
Blinding | NA | NA
Length of followup | 5 yr | Variable
Outcome: Clinical improvement | No | No
Outcome: Hemodynamics | No | No
Outcome: Imaging | No | No
Outcome: Patency | Yes | Yes
Outcome: Amputation | No | No
Outcome: Mortality | Yes | Yes
Outcome: Reinterventions | No | No
Outcome: Complications | Yes | Yes
Quality | C | C

Table 19 Characteristics of TASC II citations regarding endovascular treatments for aorto-iliac disease

Characteristic | Murphy 2004^54^ | Dutch 2004^55–57^ | Bosch 1997^31^ | Ponec 2004^58^
Study type | Retrospective cohort | RCT | Systematic review of cohort studies | RCT
No. subjects | 365 | 213 | PTA: 1300 (6 studies) Stent: 816 (8 studies) | 203
Multicenter? | No | Yes | (Yes) | Yes
A priori sample size calculation? | No | Yes | NA | Yes
Allocation concealment? | NA | Yes | NA | Unclear
Clinical classification by SVS? | No | (Fontaine) | (Claudication vs. limb salvage) | (Claudication vs. limb salvage)
Hemodynamic classification? | Yes | Yes | Yes | Yes
TASC/Anatomic classification | (Stenosis vs. occlusion) | (SCIVR) | (Percent occlusion) | (Length of stenosis)
Baseline comparability | NA | Yes | NA | Yes
Intention to treat analysis? | NA | Yes | NA | Yes
Reason for dropouts | NA | No | NA | Yes
Blinding | NA | No | NA | No
Length of followup | 33 mo | 6 yr | Variable | 9 mo
Outcome: Clinical improvement | Yes | Yes | No | Yes
Outcome: Hemodynamics | Yes | Yes | Yes | Yes
Outcome: Imaging | Yes | Yes | Yes | Yes
Outcome: Patency | Yes | Yes | Yes | Yes
Outcome: Amputation | No | No | No | No
Outcome: Mortality | Yes | No | Yes | Yes
Outcome: Reinterventions | No | No | Yes | No
Outcome: Complications | Yes | No | Yes | Yes
Quality | C | A | B | B

SCIVR, Society for cardiovascular and interventional radiology.

Table 20 Characteristics of TASC II citations regarding PTA versus bypass for femoral popliteal disease

Characteristic | Wolf 1993^60^ | Adam 2005^59^
Study type | RCT | RCT
No. subjects | 263 | 452
Multicenter? | Yes | Yes
A priori sample size calculation? | nd | Yes
Allocation concealment? | Yes | Yes
Clinical classification by SVS? | (Claudication vs. limb salvage) | (Limb salvage)
Hemodynamic classification? | Yes | Yes
TASC/Anatomic classification | No | No
Baseline comparability | Yes | Yes
Intention to treat analysis? | Yes | Yes
Reason for dropouts | Yes | Yes
Blinding | No | No
Length of followup | 4.1 yr | 5.5 yr
Outcome: Clinical improvement | Yes | Yes
Outcome: Hemodynamics | Yes | No
Outcome: Imaging | Yes | No
Outcome: Patency | Yes | No
Outcome: Amputation | Yes | Yes
Outcome: Mortality | No | Yes
Outcome: Reinterventions | Yes | Yes
Outcome: Complications | No | Yes
Quality | B | A

Table 21 Characteristics of TASC II citation regarding endovascular treatments for femoral popliteal disease (not including RCTs of PTA versus stent or stent versus stent)

Characteristic | Muradin 2001^61^
Study type | Systematic review of cohort studies
No. subjects | 1396 (19 studies)
Multicenter? | (Yes)
A priori sample size calculation? | NA
Allocation concealment? | NA
Clinical classification by SVS? | Yes
Hemodynamic classification? | No
TASC/Anatomic classification | No
Baseline comparability | NA
Intention to treat analysis? | NA
Reason for dropouts | NA
Blinding | NA
Length of followup | Variable
Outcome: Clinical improvement | No
Outcome: Hemodynamics | No
Outcome: Imaging | Yes
Outcome: Patency | Yes
Outcome: Amputation | No
Outcome: Mortality | No
Outcome: Reinterventions | No
Outcome: Complications | No
Quality | C

## 3.3 Systematic Review of TASC Classification

### Overview

(Table 22)

From the horizon scan, 399 articles met criteria for retrieval (published since 2001, evaluated an invasive vascular procedure, and mentioned a clinical outcome in the title or abstract. Of these, 31 studies met criteria and were analyzed.62–92 Of the rejected studies, 339 did not report TASC classifications, 21 did not report clinical outcomes for patients within a specific TASC classification, 2 provided data for combined groups of patients receiving either stent or bypass, 1 reported results only at 3 months, and 5 were duplicate publications of included studies.

Only 16 of these studies reported outcomes by TASC classification. Only half of the eligible 31 studies reported TASC classification data in their abstracts or titles. The specific details about how the TASC classification of each patient was determined were generally not reported.

The distribution of outcomes data by artery, intervention, and TASC classification is shown in Table 22. The distribution of studies suggests that data are available to assess outcomes across TASC classifications for stenting (or PTA with or without stent placement) and to a more limited extent, for PTA alone or other interventions. Only for TASC classifications C and D combined (or in one instance TASC classification D) are there comparisons between surgical and endovascular procedures.

The percentage of studies that met eligibility criteria rose each year: 2001 0 percent; 2002 2 percent; 2003 5 percent; 2004 11 percent; 2005 15 percent; 2006 and 2007 16 percent. Thus, among studies of invasive interventions for PAD, reporting of data by TASC classification is becoming more common; though the percentage has stabilized over the past 2 to 3 years and remains low.

Table 22 Distribution of studies reporting TASC classification and clinical outcomes, by artery and intervention

Intervention | Femoral Popliteal | | | | | | Aorto-iliac | | | | | | Combination
Intervention | A | A/B | B | C | C/D | D | A | A/B | B | C | C/D | D | A | A/B | B | C | C/D | D
Bypass | | | | | 3 | | | | | | 7 | | | | | | | 1
PTA±Stent | 1 | 1 | 3 | 2 | 3 | 3 | 1 | 1 | 2 | 1 | 3 | 1 | 1 | | 1 | 2 | | 1
PTA | | | 1 | 1 | 3 | 1 | | | | | 1 | | 1^*^ | | 1^*^ | 1^*^
Other | 1 | 1 | 1 | 3 | | 2

* Tibial artery disease

### Direct comparisons

Eleven studies reported data providing direct comparisons among TASC grades65,76,77,79,80,83,86–89 or between bypass and PTA for a specific TASC grade population.75,76 Only six of these studies, though, reported statistical analyses related to TASC classification.

#### Different interventions

##### Bypass versus PTA

Kedora 2007 compared bypass and stent placement for femoral popliteal disease in an RCT of 100 limbs.76 The study included patients with all TASC grades, but 83 percent of the analyzed limbs had TASC C or D disease; therefore this study was evaluated as a TASC C/D population (68 percent TASC C). The study did not analyze their data based on TASC classification. Twelve-month amputation rates were statistically similar after both procedures (bypass 10 percent and stent 2 percent, P=.09). Mortality (9 and 11 percent) and reintervention (29 and 34 percent) rates were also similar after both procedures, though not analyzed by the authors.

Hynes 2004, in a retrospective analysis, compared bypass and PTA with or without stent placement in separate groups of patients with femoral popliteal and aorto-iliac disease.75 Only patients with TASC C or D were included. For patients with femoral popliteal disease, 54 percent of 74 patients who received PTA had TASC C disease, while only 10 percent of 28 patients who received bypass had TASC C disease; similarly for patients with aorto-iliac disease, 40 percent of 14 patients who received PTA had TASC C disease, while only 10 percent of 21 patients who received bypass had TASC C disease. Despite these baseline differences, reintervention rates were not significantly different for either intervention, regardless of artery (7 to 14 percent). Amputation rates were not statistically analyzed, but were substantially higher after bypass (14 to 18 percent) than PTA (0 to 3 percent), in both arteries. The risk difference was not statistically significant for aorto-iliac disease (14, 95% CI −0.7 to 29 percent) but was for femoral popliteal disease (15, 0.5 to 30 percent). Because of the retrospective design of this analysis, the baseline differences, and the lack of adjustment, it is not possible to distinguish whether the different amputation rates are related to the intervention or the baseline severity of disease, as indicated by the differing TASC classifications.

##### PTA with primary stenting versus selective stenting

One study of 376 patients receiving PTA with or without stents for femoral popliteal disease reported that there was no difference between primary stenting and selective stenting, stratified by TASC lesion (A to D).88 However, no data were reported.

##### Summary

Three studies compared either bypass to PTA or PTA with primary or selective stenting. The studies are limited by their design, generalizability, and incomplete reporting and analysis, but do not provide evidence that any procedure results in better clinical outcomes for patients based on TASC classification.

#### TASC classifications

##### Clinical status

Four studies reported data on symptomatic improvement based on TASC classification.65,79,86,88 All evaluated PTA with or without stent; one evaluated patients with aorto-iliac disease, one with femoral popliteal disease, and two with combination disease; one restricted eligibility to patients with TASC C and D, the remaining included patients with all TASC classifications. Only one study reported statistically significant differences across TASC classifications. In a study of PTA with or without stent in 441 patients with femoral popliteal disease, patients with TASC A or B were significantly less likely to have no symptomatic improvement than those with TASC C or D disease (13 versus 23 percent; P=.047).88 A second study of stents for 89 patients with TASC C or D combination artery disease found a substantial, but nonsignificant difference in likelihood of no symptomatic improvement (3 versus 12 percent); though the statistical analysis was not performed by the authors.65 The two remaining studies found similar rates of no symptomatic improvement across TASC classifications for PTA with or without stent in either aorto-iliac (151 patients) or combination artery (256 patients) disease (20 to 27 percent, except for 1/14 patients with TASC C disease in one study).79,86

##### Amputation

Six studies reported data on amputation rates across TASC classifications. 77,79,83,87–89 One study evaluated atherectomy; the others PTA with or without stent. Three included patients with femoral popliteal disease, two aorto-iliac disease, and one tibial disease. One excluded patients with TASC A disease, the remaining included patients with all TASC classifications. No study reported a statistically significant difference in amputation rate at the P=.05 level. One study of 52 patients receiving PTA for tibial disease found that TASC C lesions had higher rates of amputation than A or B (6/14 versus 1/17 and 0/16, P=.07).87 One study of stent in 89 patients with aorto-iliac disease reported that patients with TASC B disease had lower amputation rates than TASC C or D, but this difference was not statistically significant (0 versus 3 or 5 percent, not analyzed by authors).83 Another study found the same amputation rates among 70 patients having atherectomy for femoral popliteal disease in with TASC classifications A/B, C, and D.77 Two other studies with a total of 452 patients also found higher amputation rates with TASC D disease after PTA for femoral popliteal disease (10 and 20 percent) than TASC A to C disease (0 percent in one study, about 12 percent in the second study).88,89 A final study of PTA with or without stenting in 151 patients with aorto-iliac disease found no significant difference among TASC A, B, or C/D patients (5, 1, and 7 percent, respectively).79

##### Reintervention

Three studies reported data on reintervention rates across TASC classifications.65,77,80 One study evaluated atherectomy in 70 patients with femoral popliteal disease found a significantly greater risk of reintervention with TASC D disease (32 percent) compared to TASC A or B (0 percent); patients with TASC C disease had an intermediate reintervention rate (9 percent); the statistical analyses were not reported by the authors.77 The study of stents for combination disease in 89 patients with either TASC C or D disease and the study of cryoplasty for femoral popliteal disease in 102 patients with TASC A to C disease both found no statistically significant difference in reintervention rates; though rates were greater in patients with greater severity of disease (8 versus 3 percent [D versus C] and 20, 15, and 11 percent [C, B, an d A]).65,80

##### Mortality and quality of life

No study compared mortality rates or quality of life across TASC classifications.

##### Summary

The studies tended to be underpowered to detect statistically significant differences across TASC classifications, largely because of small numbers of patients within specific TASC levels. Nevertheless, across interventions, arteries, and outcomes, but within studies, there was the common trend that patients with higher levels of disease had worse clinical outcomes.

### Indirect comparisons

(Figures 4–8)

We constructed graphs depicting the proportion of people with a clinical event (death, reintervention, amputation, no clinical improvement) for each combination of intervention, artery and TASC category. Overall, 31 different studies provided such information for the clinical outcomes of interest (quality of life was reported in a single study69 and is therefore not considered further).62–92

The majority of the data come from single cohorts of patients where no direct comparisons were reported between interventions or among TASC classifications. Therefore, the analyses from these studies should be used primarily to generate hypotheses to be tested by future research and, importantly, should not be used to draw definitive conclusions on the relative effectiveness of different interventions across arteries or TASC categories. Moreover, there are numerous confounding variables based on the differing study designs, baseline characteristics, eligibility criteria, and treatment thresholds across the studies. For this reason, estimates of prevalence of clinical outcomes in each patient subgroup must be interpreted with caution.

Allowing for the aforementioned caveats, we make general descriptive comments for each of the four analyzed clinical outcomes.

#### Clinical status

(Figure 4)

Figure 4 illustrates the percentage of patients without clinical improvement across different TASC categories for each artery type and each intervention. Seven studies reported this outcome, most of which used PTA with (elective) stenting.63,65,79,86,88,90,92

In studies that allowed direct comparisons, outcomes tended to worsen with TASC category: most connecting lines in Figure 4 have a positive slope (see also the “Direct Comparisons” section above). Overall, across all studied subgroups, there is a general tendency for worse outcomes in higher TASC categories. There is insufficient evidence among these studies to discern which intervention results in the most clinical improvement within any TASC classification.

Figure 4 Proportion of patients with lack of clinical improvement per intervention, artery and TASC group

B: Bypass, O: Other intervention (endarterectomy, atherectomy, orcryoplasty); P: PTA without stenting; S: PTA with primary or elective stenting. Other artery: tibial or combination of different arterial lesions.

Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (B, P, S, O), artery treated (aorto-iliac, femoral popliteal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (see figure key). For each artery, subgroups of patients from the same study are connected with lines.

Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

Complex graphic displaying the percent of subects with no clinical improvements in individual studies categorized by TASC classification and intervention type. Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (bypass, PTA, stent, other intervention), artery treated (aorto-iliac, femoral politeal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (go to figure key). For each artery, subgroups of patients from the same study are connected with lines. Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

#### Amputation

(Figure 5)

Figure 5 illustrates the percentage of patients who had amputations from 23 studies.62,63,67–69,73–79,81–85,87–92 In studies that allowed direct comparisons, outcomes tended to worsen with worsening TASC category: most connecting lines that span different TASC categories have a positive slope in Figure 5 (see also the “Direct Comparisons” section above). Overall, across all studied subgroups, there is general tendency for worsening outcomes in higher TASC categories. There is insufficient evidence among these studies to discern which intervention results in the most clinical improvement within any TASC classification.

Figure 5 Proportion of patients who had amputation per intervention, artery and TASC group

B: Bypass, O: Other intervention (endarterectomy, atherectomy, orcryoplasty); P: PTA without stenting; S: PTA with primary or elective stenting. Other artery: tibial or combination of different arterial lesions.

Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (B, P, S, O), artery treated (aorto-iliac, femoral popliteal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (see figure key). For each artery, subgroups of patients from the same study are connected with lines.

Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

Complex graphic displaying the percent of subects with amputations in individual studies categorized by TASC classification and intervention type. Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (bypass, PTA, stent, other intervention), artery treated (aorto-iliac, femoral politeal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (to go figure key). For each artery, subgroups of patients from the same study are connected with lines. Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

#### Reintervention

(Figure 6)

Figure 6 illustrates the percentage of patients who had reinterventions from 22 studies.62–78,80,82,84,85,92 In studies that allowed direct comparisons, outcomes tended to worsen with worsening TASC category: most connecting lines that span different TASC categories have a positive slope in Figure 6 (see also the “Direct Comparisons” section above). Overall, across all studied subgroups, there is general tendency for worsening outcomes in higher TASC categories. There is insufficient evidence among these studies to discern which intervention results in the most clinical improvement within any TASC classification.

Figure 6 Proportion of patients receiving reinterventions per intervention, artery and TASC group

B: Bypass, O: Other intervention (endarterectomy, atherectomy, orcryoplasty); P: PTA without stenting; S: PTA with primary or elective stenting. Other artery: tibial or combination of different arterial lesions.

Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (B, P, S, O), artery treated (aorto-iliac, femoral popliteal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (see figure key). For each artery, subgroups of patients from the same study are connected with lines.

Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

Complex graphic displaying the percent of subects with reinterventions in individual studies categorized by TASC classification and intervention type. Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (bypass, PTA, stent, other intervention), artery treated (aorto-iliac, femoral politeal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (go to figure key). For each artery, subgroups of patients from the same study are connected with lines. Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

#### Mortality

(Figure 7)

Figure 7 illustrates the percentage of deaths across different TASC categories for each artery type and each intervention from 15 studies. 62,64,66,68,69,71–74,76,81,82,84,85,91 As shown, deaths were reported mainly for patients with severe (TASC C or D and D) lesions. Bypass was performed mainly for aorto-iliac disease, whereas PTA with or without stenting was more commonly used among those with femoral popliteal or tibial disease. Overall, across all studied subgroups, there is general tendency for worsening outcomes in higher TASC categories. There is insufficient evidence among these studies to discern which intervention results in the most clinical improvement within any TASC classification.

Figure 7 Proportion of deaths per intervention, artery and TASC group

B: Bypass, O: Other intervention (endarterectomy, atherectomy, orcryoplasty); P: PTA without stenting; S: PTA with primary or elective stenting. Other artery: tibial or combination of different arterial lesions.

Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (B, P, S, O), artery treated (aorto-iliac, femoral popliteal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (see figure key). For each artery, subgroups of patients from the same study are connected with lines.

Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

Complex graphic displaying the percent of subects who died in individual studies categorized by TASC classification and intervention type. Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (bypass, PTA, stent, other intervention), artery treated (aorto-iliac, femoral politeal, other), and TASC category (A, A/B, B, C, C/D, D). The TASC categories are listed in the horizontal axis. Within each TASC category the 4 different intervention groups are represented by 4 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape and color (go to figure key). For each artery, subgroups of patients from the same study are connected with lines. Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

#### Visualization of outcome rates across different interventions

(Figure 8)

Figure 8 juxtaposes the four clinical outcomes (lack of clinical improvement, amputation, reintervention and mortality) among patients with TASC C or D lesions. In this figure, PTA with or without stenting is compared to bypass surgery.

In studies with direct comparisons (connecting lines in Figure 8) there are inconsistent indications as to which treatment results in better clinical outcomes. Looking at the individual cohort data, the highest rates of poor outcomes occurred in cohorts of patients receiving PTA or stenting. However, this may equally be the result of confounding due to different characteristics and eligibility criteria across the studies or due to true superior results after bypass.

Figure 8 Proportion with a clinical outcome during study followup per intervention and artery among patients with TASC C or D lesions

B: Bypass, P: PTA with or without stenting

Each marker represents a subgroup of patients per study. Subgroups are defined according to intervention received (B, P), artery treated (aorto-iliac, femoral popliteal). Different clinical outcomes are listed in the horizontal axis. For each clinical outcome the 2 different intervention groups are represented by 2 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape (see figure key). For each artery, subgroups of patients from the same study are connected with lines.

Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

Figure 8 juxtaposes the proportion of patients with a clinical outcome during study followup per intervention and artery among patients with TASC C or D lesions. Each marker in the figure represents a subgroup of patients per study. Subgroups are defined according to intervention received (B, P), artery treated (aorto-iliac, femoral politeal). Different clinical outcomes are listed in the horizontal axis. From left to right, the outcomes are death, reintervention, amputation and no improvement. For each clinical outcome the 2 different intervention groups are represented by 2 thin frames (labeled empty boxes). Treated arteries are distinguished by different marker shape (go to figure key). For each artery, subgroups of patients from the same study are connected with lines. Of note, this graphical abstraction is subject to confounding by study and by indication for treatment, and is not a substitute for within-study adjusted statistical analyses.

## 3.4 Systematic Review of Comparative Stent Studies

### Key Question Perform systematic review of the relative safety and effect of peripheral artery stenting with other invasive vascular procedures for occlusive PAD of infrarenal vessels. Also evaluate comparisons of different stents and/or different procedures with stents

#### Organization of systematic review results section

This systematic review (section 3.4) covers comparisons of several interventions, clinical outcomes, and procedural complications. After a general description of the literature search and evaluated studies, the results are organized as follows:

3.4.1 Stent versus PTA
  - Individual descriptions of RCTs
  - Clinical outcomes
    - Clinical status
    - Amputation
    - Reintervention
    - Mortality
    - Walking distance
    - Ankle-brachial index (ABI)
    - Miscellaneous outcomes (other vascular, quality of life)
3.4.2 Stent versus bypass
  - Clinical outcomes
3.4.3 Stent versus stent
  - Bare versus drug-eluting stents
  - Stent+brachytherapy versus stent alone
    - Clinical outcomes
3.4.4 Procedural complications
  - Major and minor complications
  - Major and minor bleeding
  - Emboli
  - 30-day mortality

Within each outcome, the studies that evaluated aorto-iliac, femoral popliteal, and tibial disease are reviewed separately, where applicable.

#### Literature search and evaluated studies

(Table 23, Figure 9)

From the 14,815 citations (see Appendix A for search strategy), of which 2,488 met criteria for the horizon scan, 82 full-text articles were retrieved for review. One RCT was added by domain experts for the systematic review. The remaining publications did not meet criteria based on their titles and abstracts. Among these, 27 studies (in 33 publications) met criteria and are included. Figure 9 details the flow of studies and reasons for exclusion. Appendix B lists the reviewed but rejected publications, including the reasons for rejection.

The studies included 13 RCTs, 4 prospective comparative studies, and 10 retrospective comparative studies. The studies, in general, and the trials, specifically, were highly clinically heterogeneous regarding the type of stent used, the use of stent placement as a secondary intervention in the PTA arm (crossover), the severity and anatomy of PAD, the proportion of patients with cardiovascular risk factors, the dates of the interventions, the duration of followup, and the outcomes assessed.

Figure 9 Study flow diagram

arrows for flow chart

Table 23 displays which clinical outcomes and procedure complications each study reported. The RCTs were more likely to report the long-term clinical outcomes than the prospective or retrospective nonrandomized studies. However, as is evident from the table, there was little uniformity in the reporting times, though data were more likely to be reported at 1 year than other times. ABI and clinical status were the most commonly reported clinical outcomes. However, as described below, a wide range of definitions of clinical status were used by the various studies. Amputation rates, reinterventions (subsequent vascular procedures for the treated artery), and mortality were reported by most RCTs. Walking distance was reported only by four RCTs. Only one trial has evaluated quality of life. Most studies reported overall complications and bleeding (major and to a lesser extent minor for both outcomes) within 30 days of the procedures, however, varying definitions of these outcomes were used. Embolic events related to the procedures were reported in half the RCTs but only one other study. Thirty-day mortality was more commonly reported in the observational studies. Only four studies reported stent fracture rates.

Table 23 Outcomes evaluated and time of assessment in included studies

Study Year | Clinical Outcomes (Times outcomes evaluated) | | | | | | | Complications
Study Year | Clinical Status | Amputation | Reinter- vention | Mortality | Walking distance | ABI | QoL | Overall Complications, 30 day | Bleeding, 30 day | Embolic Events, 30 day | 30-day mortality | Stent Fracture
RCTs
Krankenberg 2007^40^ | 1 yr | 1 yr | 1 yr | 1 yr | 1 yr | 1 yr | | X | X | X | | 1 yr
Becquemin 2003^93^ | 4 yr | 4 yr | 4 yr | 4 yr | | 1 yr | | X | X | X | X
Cejna 2001^94^ | 1 yr | | 1 yr | 1 yr | | | | X | X | X | X
Dutch Iliac Stent Trial 1998^55–57,95,96^ | 1, 2, 6–8 yr | 6–8 yr | 6–8 yr | 5.6 yr | 1, 2 yr | 1, 2, 6–8 yr | 1, 2, 5 yr | X
Duda 2006^97^ | 1.5, 2 yr | 2 yr | 1, 2 yr | 2 yr | | 2 yr | | | | | | 18 mo
Grimm 2001^98^ | | | ~11 mo | nd | nd | nd | | X | X
Kedora 2007^76^ | nd | 1 yr | | nd | | 1 yr | | X | X
Rand 2006^99^ | | 5.5 mo | 5.5 mo
Saxon 2003^100^ | 0.5, 2 yr | | | | | 0.5, 2 yr | | | X | X
Schillinger 2006^101,102^ | 1, 2 yr | 1, 2 yr | 2 yr | 1 yr | 1, 2 yr | 1, 2 yr | | X | | X | | 1 yr
Vroegindeweij 1997^103^ | 1 yr | | | | | 1 yr | | | X | X
Wolfram 2005^104^ | 1, 2 yr | | | | 1 yr | 0.5, 1 yr | | X | X | X
Zdanowski 1999^105^ | 1 yr | | | | | 1 yr | | X | X | | X
Prospective
Bosiers 2006^106^ | | 0.5 yr
Do 1992^107^ | | | 1 yr
Schillinger 2002^108^ | | | | | | 0.5 yr
Siablis 2005^109,110^ | 0.5 yr | 0.5, 1 yr | 0.5, 1 yr | 0.5, 1 yr | | 0.5 yr | | X | X | | X | 30 d
Retrospective
Ballard 1998^111^ | | | | 22 mo | | “Early” | | | | | X
Burns 2000^112^ | | | | | | | | X | X
Cho 2003^113^ | | | | | | nd | | X
Kudo 2005^79^ | 10 mo | 10 mo | 10 mo | | | | | X | X | | X
Laxdal 2007^114^ | | | | | | | | X | X | | X
Pozzi Mucelli 2003^115^ | | | | | | nd | | X | X | X | X
Schillinger 2003^116^ | | | | | | | | X
Westcott 1998^117^ | 1 yr | | | | | 1 yr | | | X

### 3.4.1 Stent versus Angioplasty (PTA)

#### Description of RCTs

Ten trials evaluated stent versus PTA. The trials analyzed a total of 1190 patients (range 28 to 279, median 78 patients per trial). By anatomic segment, one addressed the aorto-iliac segment, eight the femoral popliteal segment, and one the infrapopliteal (tibial) segment. Overall, seven used balloon-expandable stents and three self-expandable. One trial used treated balloon-expandable stents and one trial used covered self-expandable stents; the remaining used bare stents. Four of the trials were of good quality, one fair quality, and five of poor quality. The poor quality studies suffered from inadequate reporting of design, definitions, or data, inadequate analyses, poorly reported or inadequate randomization and allocation concealment, very small sample size, high dropout rates, or combinations of these problems. Two studies had high applicability to the Medicare population of patients requiring PAD interventions; eight were of medium applicability, generally due to restrictive eligibility criteria; and one of narrow applicability, due to its analysis of fewer than 30 patients. All but one trial included patients with a mean age over 65 years, though all included patients in their 40s and 50s.

##### Aorto-Iliac Segment

###### Dutch Iliac Stent Trial55–57,95,96

The trial compared Palmaz (bare, balloon-expanded) stent to PTA in 279 patients. Included patients had at least 50 percent stenosis or elevated pressure gradient in the iliac arteries. Stenoses over 10 cm and occlusions over 5 cm were excluded. The procedures were performed between 1993 and 1996. The results were reported in 5 articles published over 7 years. The longest mean followup was 6.3 years (up to 8.6 years). Aspirin or other anticoagulants were used per local guidelines or per the referring physicians’ preferences.

Patients had a mean age of 58 years; 72 percent were male, 10 percent had diabetes, 90 percent had a smoking history, 28 percent had hypertension, and 25 percent hyperlipidemia. Most patients (90 percent) had claudication, while 3 percent were asymptomatic, and 7 percent had tissue necrosis; 10 percent had occlusions.

Outcome assessors were blinded, but not patients. Randomization and allocation concealment were adequate. Up to 10 percent of patients did not have followup for various outcomes. Notably, as per protocol, 43 percent of patients assigned to primary PTA had secondary stent placement because hemodynamically significant gradients remained after PTA. Intention-to-treat analyses were performed.

The trial was rated good quality with medium applicability.

##### Femoral Popliteal Segment

###### Vroegindeweij 1997^103^

Palmaz (bare steel, balloon-expandable) stents were compared to PTA in 51 patients. Patients had mild to severe claudication due to femoral popliteal lesions that were less than 5 cm. Patients with lesions below the knee, multisegmental disease, or with no runoff were excluded. Patients had no previous intervention on the affected femoral artery. The procedures were performed between 1993 and 1995, and patients were followed for a median of 14 months (between 0 and 31 months). Patients who received stents were anticoagulated for 3 months.

Patients had a mean age of 65 years (range 41 to 82 years). Seventy-one percent were male; 12 percent had diabetes, 63 percent had a smoking history, 18 percent had hypertension, 31 percent had hyperlipidemia, and 29 percent had concomitant cardiac disease. Few patients (18 percent) had severe claudication. Apparently none had critical limb ischemia, though 18 percent had occlusions.

Patients and outcome assessors were not blinded to intervention. No description of an adequate randomization method or allocation concealment was reported. All enrolled patients were analyzed and the patients receiving each intervention were similar at baseline. Four (17 percent) of the patients randomized to receive stent had angioplasty alone because of technical failure to deploy the stents; an intention-to-treat analysis was performed.

The study was rated to be of fair quality and medium applicability.

###### Zdanowski 1999^105^

Strecker (flexible bare tantalum, balloon-expandable) stents were compared to PTA in 32 patients. Patients had claudication or more severe symptoms due to femoral popliteal lesions. Eligibility criteria were not well described. The dates of the procedures were not reported. Patients were followed for 1 year after the interventions.

Patients had a median age of 71 years (range 41 to 86 years). Two-thirds of those who received stent were male, but only 24 percent of those receiving PTA alone were male; 31 percent had diabetes, 34 percent had had a smoking history, 25 percent had hypertension. Two-thirds of patients had ulcerations; 19 percent had rest pain; 14 percent had claudication. All were reported to have occlusions.

No data on blinding were reported. The authors reported an adequate randomization method and allocation concealment. Between 9 and 22 percent of patients were not analyzed for various outcomes; intention-to-treat analyses were not conducted. All patients received the intervention to which they were assigned.

The study was rated to be of poor quality with medium applicability.

###### Cejna 2001^94^

Palmaz (bare steel, balloon-expandable) stents were compared to PTA in 141 patients (154 limbs). All results were reported per limb, not per patient. Patients with intermittent claudication or chronic critical limb ischemia due to femoral popliteal disease that was less than 5 cm were enrolled. Patients with previous vascular surgery in the treated segments were excluded. The procedures were performed between 1994 and 1997. Patients were followed for a mean of 1 year (range 1 day to 3.4 years). All patients received aspirin as a continuous, life-long medication. Intravenous heparin was used for 2 days.

Patients had a mean age of 67 years (range 39 to 87 years). Most (62 percent) were male; 40 percent had diabetes, 62 percent had a smoking history, 41 percent had hyperlipidemia. By the SVS-ISCVS classification, 16 percent had mild or moderate claudication, 55 percent severe claudication, 12 percent rest pain, and 18 percent minor tissue loss; 39 percent had occlusions.

Patients and outcome assessors were not blinded. The randomization method was not reported, but an adequate system for allocation concealment was used. Between 10 and 20 percent of limbs were not analyzed for various outcomes. Stents were placed in 13 percent of limbs assigned to PTA for secondary reasons. One patient had a stent that failed to deploy; this patient had bypass surgery. Intention-to-treat analyses were employed.

The study was rated to be of fair quality and high applicability.

###### Grimm 2001^98^

Palmaz (bare steel, balloon-expandable) stents were compared to PTA in 53 patients. Included patients had occlusion or severe stenosis (≥70 percent) in the superficial femoral artery or proximal popliteal artery that was less than 5 cm, with sufficient runoff. Patients with more distal disease or thrombus within the femoral artery were excluded. The dates of the procedures were not reported. Patients were followed for an average of 29 and 34 months after stent or PTA, respectively; the primary endpoint was at 12 months. Heparin and aspirin were used at the time of the procedures and patients were given aspirin 100 mg/day to take life-long.

Patients had a mean age of 70 years; 60 percent were male. No data were provided on rates of cardiovascular risk factors or concomitant disease, but it was reported that there were no statistically significant differences between the trial arms. The mean SVS score was 2.3 and the mean Fontaine classification was 2.7; 19 percent had claudication, 36 percent had rest pain, and 43 percent had tissue loss; 30 percent had occlusions. Notably, there were large differences at baseline for several variables, though none of the differences was statistically significant (male: stent 73 versus PTA 43 percent; occlusion: stent 43 versus PTA 13 percent; mean ABI: stent 0.47 versus PTA 0.62).

No data were reported about blinding. The randomization method was adequate, but the method of allocation concealment was unclear. It was unclear whether intention-to-treat analyses were performed. All patients had the intervention to which they were assigned and there were no dropouts reported. The timing of outcomes was poorly reported and the analyses did not directly compare the interventions.

The trial was rated to be of poor quality with medium applicability.

###### Becquemin 2003^93^

Palmaz (bare steel, balloon-expandable) stents were compared to PTA in 227 patients. Patients with stage lib to IV stenosis or occlusion of the superficial femoral artery between 1 and 7 cm in length and sufficient outflow were included. Only a single lesion in the artery was allowed. Patients with acute ischemia, distal disease, and previous revascularization of the artery to be treated were excluded. The procedures were performed between 1995 and 1997. Patients were followed for a median of 2.4 years (up to 4 years); the primary endpoint was 12 months. Heparin was used periprocedure.

Patients had a mean age of 67 years; 63 percent were male, 12 percent had diabetes, 59 percent had a smoking history, 52 percent had hypertension, 41 percent had hyperlipidemia, and 26 percent had concomitant cardiac disease. Most patients had claudication (79 percent), 6 percent had rest pain, and 15 percent had focal tissue necrosis; 20 percent had occlusions.

No data were reported about blinding. Adequate methods were reported for randomization and allocation concealment. Loss to followup was unclearly reported; 13 percent of patients assigned to PTA had a stent placed for suboptimal angioplasty; it was implied that all patients assigned to stent had the procedure. Intention-to-treat analyses were used. Independent reviewers were used for clinical outcomes.

The trial was rated to be of good quality (except for ABI outcomes, which was poor quality, because only 20 patients had followup at 1 year) and medium applicability.

###### Saxon 2003^100^

A nitinol (self-expanding) stent with a thin wall ePTFE lining was compared to PTA in 28 patients. Patients had claudication or ischemia due to superficial femoral artery or proximal popliteal artery lesions less than 13 cm in length. Patients with small vessels, extensive disease, or insufficient runoff were excluded. The procedures were performed in 1998 and 1999. Patients were followed for an average of 38 months (range 28 to 48 months) with a primary endpoint at 24 months. Aspirin 325 mg/day was prescribed to all patients; most also took either ticlopidine or clopidogrel.

Patients had a mean age of 70 years; the percent male was not reported; 39 percent had diabetes, 39 percent had a smoking history, 71 percent had hypertension, 64 percent had hyperlipidemia, and 49 percent had concomitant cardiac disease. The mean SVS category was 2.3; 78 percent had TASC classification B, 3 percent A, and 19 percent C; 10 percent had occlusions.

Neither patients nor outcome assessors were blinded. Randomization and allocation concealment were not adequate; 2 of 15 patients assigned to stent were assigned as training cases, not through randomization. Intention-to-treat analyses were used; 6 percent of patients assigned to PTA had stents placed; all stents successfully deployed.

The trial was rated to be of poor quality and narrow applicability.

###### Schillinger 2006^101,102^

Nitinol (self-expanding) stents were compared to PTA in 104 patients. Patients had severe claudication or more severe disease (SVS 3 to 5) from stenoses of at least 50 percent in the superficial femoral artery; lesions were at least 3 cm long. Patients were excluded if they had acute ischemia, previous surgery or stenting of the femoral artery, inflow disease or no runoff. The procedures were performed in 2003 and 2004. The primary endpoint was 6 months, with followup up to 24 months. Aspirin and clopidogrel were used after both procedures.

Patients had a mean age of 67 years; 53 percent were men, 37 percent had diabetes, 44 percent had a smoking history, 91 percent had hypertension, 89 percent had hyperlipidemia, and 71 percent had concomitant cardiac disease. Notably, these patients had substantially higher rates of elevated cardiovascular risk factors and cardiac disease than other trials. Most (88 percent) had severe claudication, 3 percent had rest pain, and 9 percent had tissue loss; 36 percent had occlusions.

Outcome assessors were blinded, but not patients. The trial used adequate methods for randomization and allocation concealment. All enrolled patients were analyzed by intention-to-treat methods. As per protocol, 33 percent of patients assigned to PTA had secondary stenting for suboptimal results after two prolonged dilations. All stents successfully deployed.

The trial was rated as being of good quality and high applicability.

###### Krankenberg 2007^40^

In the Femoral Artery Stenting Trial (FAST), a self-expanding nitinol stent was compared to PTA in 224 patients. The trial included only patients with de novo isolated SFA lesions with at least moderate claudication (Rutherford category 2) and stenosis over 70 percent. Patients with long lesions (more than 10 cm in individual lesion or total length across lesions), whose disease extended into the popliteal artery, or had lack of runoff were excluded. The patients were randomized in 2004 and 2005. Aspirin and clopidogrel were used in patients who received PTA and stent, respectively. The endpoints were reported at 12 months.

The mean age was 66 years; 69 percent were male; 34 percent had diabetes; 65 percent had a smoking history, 36 percent had concomitant cardiac disease (42 percent in stent arm, 31 percent in PTA arm; implied nonsignificant difference); two-thirds had severe claudication (Rutherford 3), 3 percent had more severe symptoms; 37 percent of patients assigned to stent had occlusions as opposed to 25 percent assigned to PTA (P=.053).

It was implied that outcome assessors who measured patency were blinded to intervention, but blinding of clinical outcomes was not reported. Intention-to-treat analyses were reported. For selected outcomes, on-treatment analyses were also reported. As per protocol, 13 of 121 (11 percent) of patients assigned to PTA had a stent placed after two technically unsuccessful angioplasties (residual stenosis greater than 50 percent). Target lesion revascularization and overall mortality were analyzed in 90 percent of subjects; however, treadmill distance, ABI, and improvement in Rutherford classification were reported in only 136 patients (56 percent).

Overall, the study was rated to be of good quality, though poor quality for most outcomes due to very high dropout rate, with medium applicability to the Medicare population.

##### Infrapopliteal Segment

###### Rand 2006^99^

Carbostents (treated balloon-expandable) stents were compared to PTA in 51 patients. The trial included patients with critical chronic limb ischemia (Fontaine 3 or 4) with isolated stenosis of at least 70 percent in tibial arteries. Patients with multiple (>3) or long (>3 cm individually or 9 cm cumulatively) lesions were excluded, as were those with inflow obstruction, previous stent placement at the target lesions, or lack of runoff. In addition people with gastrointestinal bleeds or ulcers in the previous 6 months were excluded. The dates of the procedures were not reported. Patients were followed for an average of only 5.5 months, though the primary endpoint was at 6 months; patients were followed up to about 15 months. Heparin was used during the procedures, enoxaparin for 3 days after the procedures, and aspirin indefinitely. In addition, patients having a stent received clopidogrel for 4 weeks.

The mean age was 72 years (range 47 to 80 years); the sex distribution was not reported; 59 percent had diabetes (stent 46 percent, PTA 70 percent); 61 percent had a smoking history, 40 percent had concomitant cardiac disease; 76 percent had focal tissue necrosis, the remaining 24 percent had rest pain; 12 percent had occlusions.

Outcome assessors were blinded to intervention, though patients could not be. The randomization and allocation concealment methods were unclear. Intention-to-treat analyses were not performed. One patient assigned to PTA received a stent; one stent failed to deploy. There were several instances where the number of patients described and analyzed varied. Mortality was evaluated in all 51 patients, though the procedures were described in only 45 patients; 8 patients were reported to be lost to followup, but 14 patients were not included in most outcome analyses.

The study was rated to be of poor quality with narrow applicability.

##### Overall

Ten RCTs have compared stents to either PTA or PTA with selective stenting; one additional study compared stent to surgery.76 Balloon expandable stents were employed in six earlier studies, covered stents (PTFE on nitinol exoskeleton) in two, and nitinol in three, one of which compared bare nitinol to drug-eluting nitinol. The length of the atherosclerotic lesion and runoff were employed as exclusion criteria in the majority of studies. In earlier studies, which employed Palmaz stents, the extent of atherosclerotic plaque undergoing treatment generally was limited to lesions less than 5 cm in length. Treatment crossover, usually from PTA to stent when a limb in the PTA arm had a less than desirable response to PTA, was common. The incidence of conversion varied from 0 percent in two balloon expandable stent trials (Zdanowski 1999 and Grimm 2001) through 13 percent in two other trials that also employed Palmaz stents (Cejna 2001 and Becquemin 2003). Schillinger 2006 allowed optional secondary stenting for PTAs that were suboptimal, which accounted for 36 percent of patients assigned to PTA, while Krankenberg 2007 had a lower 13 percent incidence of converting from PTA to stent placement. Vroegneder 1997 was the only study with more than 1 percent of patients converting from stent to PTA, accounting for 8 percent of subjects. While intention-to-treat analysis accounts for these crossovers from one study arm to the other, the high rates of crossover in some study make interpretation of the comparisons difficult. In theory the crossover may have improved the results in the PTA arms because limbs with potentially bad outcomes with PTA alone were treated more aggressively with stents. These studies with high crossover rates must be interpreted as comparisons between the initial plans of performing PTA alone, with the option of stent placement if deemed necessary, and of placing a stent in all patients.

#### Clinical Status

(Table 24)

##### Studies

Eight RCTs40,57,93,94,100,102,103,105 and two retrospective studies79,117 reported on changes in clinical status comparing stent versus PTA. Three RCTs were of good quality, one fair quality, and four poor quality for this outcome; the two retrospective studies were, by definition, rated to be of poor quality. Three RCTs had high applicability to the Medicare population of patients requiring PAD interventions, four had medium applicability, and one narrow applicability. The retrospective studies were of high and narrow applicability.

Five of the RCTs and one retrospective study evaluated bare, balloon-expanded stents, two RCTs used a bare, self-expanding stent, and one RCT used covered, self-expanding stents. One retrospective study included both balloon- and self-expanding stents. All but one of the RCTs included patients with femoral popliteal disease, the remaining studies included patients with iliac or infrarenal aortic disease. Patients were followed for a wide range of time, from 6 months to 8 years. Eight of the studies reported results at about 1 year.

##### Outcome definitions

One study reported changes in Fontaine classification.57 Seven studies reported changes in SVS classification (otherwise known as the Rutherford stages).40,79,93,94,100,102,117 Two studies created their own systems for assessing clinical improvement.103,105 Vroegindeweij 1997 created a scoring system based on changes in SVS classification and ABI; Zdanowski 1999 defined clinical improvement by “an improvement in claudication distance by at least 50 percent, resolution of rest pain, or healing of ulcers.”

##### Results

###### Randomized Controlled Trials

Between 28 and 227 patients were analyzed in the trials. In the two largest trials, 80 to 90 percent of the patients had intermittent claudication prior to intervention.57,93

Iliac. The Dutch Iliac Stent Trial study found no significant difference in clinical status, as measured by the Fontaine score, at multiple time points up to 6 to 8 years.

Femoral popliteal. The three studies that evaluated self-expanding stents (Krankenberg 2007, Schillinger 2007, and Saxon 2003) all found no statistically significant difference in clinical status at 6 or 12 months between patients randomized to stent or PTA. Only Saxon 2003 reported data indicating a statistically significant difference by odds ratio, in one of its measures of clinical status, “clinical success” at 24 months, strongly favoring stent over PTA.100 However, importantly, the authors did not perform this analysis or report this as a significant finding. While the high crossover rate from PTA to stent in Schillinger 2007 may partially explain the lack of a difference in clinical status after 1 or 2 years, the low rate of poor status in this small RCT makes it unlikely that a statistically significant difference could have been achieved.

Among the four studies of balloon expandable stents (Becquemin 2003, Cejna 2001, Vroegindeweij 1997, and Zdanowski 1999), only Becquemin 2003 found a statistically significant difference in clinical status, measured as worsened SVS stage at 4 years, favoring PTA over balloon stent, with an odds ratio of 2.0 (95% CI 1.2–3.4).

###### Retrospective Studies

Two retrospective studies compared stent with PTA. Westcott 1998^117^ evaluated 12 patients who had abdominal infrarenal artery stent versus 13 who had PTA; Kudo 2005^79^ evaluated 34 patients with iliac artery stents versus 117 with PTA.

Infrarenal aorta. In Westcott 1998, 77 percent of patients had moderate claudication; while in Kudo 2005, most patients had either severe claudication or ischemic rest pain. Mean followup in these studies ranged from 9 to 21 months. Improvements in SVS grading were comparable between stent and PTA (11/12 versus 11/13 patients, respectively).

Iliac. Continued clinical improvement rates were not significantly different between the two groups in Kudo 2005 in univariate analysis, but it was significantly different in multivariate analysis; the group without the iliac stenting failed to have continued clinical improvement compared with the group that received the stenting (HR 3.7, P<0.02).

##### Summary

The studies were generally small and there was considerable clinical heterogeneity in the different study populations. Six of the eight trials did not find any significant difference in followup clinical status comparing stent with PTA. The one study on iliac artery intervention found no significant difference in followup clinical status comparing primary balloon-expandable stent with selective stent placement (or PTA). None of the studies of self-expanding stents in the femoral popliteal artery reported a statistically significant difference compared to PTA; though one very small study reported data indicating possibly better clinical status at 2 years after stent placement. The only statistically significant finding among the balloon-expandable stent studies in the femoral popliteal artery found that patients who received stent had worsening of the clinical stages comparing to patients who received PTA. It is plausible that the small sample sizes in these studies lacked the statistical power to detect such a difference. However, the clinical heterogeneity of the studies – different eligibility criteria and stents – together with the varying crossover rates, primarily from PTA to stent, and the wide variety of measures of clinical status used, make interpretation of the body of evidence difficult.

In summary, a weak body of evidence – due to study heterogeneity, heterogeneity of outcomes, small study size, varying crossover rates, and generally small study size – do not indicate that either stent placement or PTA alone (or planned PTA with conversion to stent placement) is superior in achieving long-term clinical success.

#### Amputation

(Table 25, Figure 10)

##### Studies

Five RCTs,40,93,96,99,102 one prospective study106 and one retrospective study79 reported on amputation rates comparing stent versus PTA. Followup time in these studies ranged from a mean of 5.5 months up to 8 years. There was little consistency in reporting times. Methodological quality was rated good in three RCTs and poor in two RCTs for this outcome, the prospective study, and the retrospective study. Three of the studies were judged to have high applicability and four medium applicability.

Three of the RCTs used bare balloon-expandable stents, one of which used carbofilm treated stents, and two used bare self-expanding stents. The nonrandomized studies used a variety of stents. Three of the RCTs included patients with femoral popliteal lesions, one iliac and one tibial lesions. One each of the nonrandomized studies evaluated patients with tibial or iliac lesions.

An important limitation of these studies regarding the clinical outcome of amputation is that only Rand 2006 (with Fontaine III or IV patients) and Kudo 2005 (a retrospective study with 50 percent of patients with chronic limb ischemia) had substantial numbers of patients at substantial risk of amputation prior to vascular interventions. Across studies there was a range in severity of disease, with critical limb ischemia in only 3 percent of patients in Krankenberg 2007^40^ and 50 percent in Kudo 2005^79^; though some studies did not report this information.

##### Outcome definitions

Both major and minor amputations were evaluated. The studies generally did not explicitly define the terms, but minor amputations are understood to mean those of the foot involving the metatarsal or digital level and major amputation are above the metatarsal, generally requiring a prosthesis.

##### Results

###### Major amputations

Seven studies on stents versus PTA (5 RCTs, a prospective and a retrospective study) evaluated major amputations. The rate of major amputations across stent arms ranged from 0 percent (1 study) to 1 out of 24 (4 percent). The corresponding range in the PTA arms was 0 percent (3 studies) to 8 out of 136 (6 percent). Figure 10 shows the results of the metaanalysis across the five RCTs (791 patients total); the Peto method was used for the metaanalysis due to rare events.48 The summary OR for stents versus PTA was 0.76 with very broad 95 percent confidence intervals (CI) (0.28, 2.05) and no evidence for heterogeneity of the results, despite the clinical heterogeneity, including the different diseased arteries and the different types of stents used. Though the range of followup times was wide, the rates of major amputations across all study arms were similar, so the summary risk difference is meaningful to calculate (−0.5 percent, 95% CI −2.8, 1.6 percent). Sensitivity analyses yielded very similar estimates. Subgroup analyses did not offer additional insights. Similar to the RCTs, the nonrandomized studies (one prospective and one retrospective) did not reveal any significant differences.

Table 24 Clinical Status: Stent versus PTA

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | Outcome | Events | OR (Significance) | Quality Applicability
RCTs
| | Iliac | Balloon
Dutch Iliac Stent Trial 1998^96^ 15286319 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 12 mo | 80 (77) | Improvement Fontaine | 64 (62) | 0.97 (NS) | A Medium
Dutch Iliac Stent Trial 1998^96^ 15286319 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 24 mo | 37 (34) | Improvement Fontaine | 29 (26) | 1.12 (NS) | A Medium
Dutch Iliac Stent Trial 1998^96^ 15286319 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 6–8 yr | 90 (78) | Improvement Fontaine | 31 (38) | 0.55 (NS) | A Medium
Dutch Iliac Stent Trial 1998^96^ 15286319 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 12 mo | 112 (107) | Fontaine | 0 (0) | -- | A Medium
Dutch Iliac Stent Trial 1998^96^ 15286319 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 24 mo | 92 (91) | Fontaine | 0 (1) | -- | A Medium
Dutch Iliac Stent Trial 1998^96^ 15286319 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 6–8 yr | 90 (78) | Fontaine | 14 (13) | 0.92 (NS) | A Medium
| | Fem-Pop | Self-expand
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | ITT: 61 (75) | Improve ≥1 Rutherford classification | 54 (69) | 0.67 (NS) | C Medium
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | On treatment: 68 (68) | Improve ≥1 Rutherford classification | 61 (62) | 0.84 (NS) | C Medium
Schillinger 2007^102^ 17502568^E^ | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 12 mo | 49 (52) | Worsen 2 SVS stages | 1 (1) | 1.06 (NS) | A High
Schillinger 2007^102^ 17502568^E^ | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 46 (52) | SVS 4–5 | 4.4% (4.2%) | ~1.05 (NS) | A High
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Self-expanding, covered | 6%/0% (ITT) | 6 mo | 15 (13) | Mean SVS (Final) | 2.6 (1.3) | Net: +0.7 (NS F) | C Narrow
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Self-expanding, covered | 6%/0% (ITT) | 24 mo | 15 (13) | Mean SVS (Final) | 2.8 (1.9) | +0.3 (NS) | C Narrow
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Self-expanding, covered | 6%/0% (ITT) | 24 mo | 15 (13) | Clinical success | 14 (6) | 16 (1.6–163) | C Narrow
| | | Balloon
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 4 yr | 115 (112) | Worsened SVS stage | 57 (37) | 1.99 D (1.16–3.4) | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | 12 mo | 71 (63) | Final SVS ≥3 | 6.8% (7.5%) | ~0.90 (NS) | B High
Vroegindeweij 1997^103^ 9354709 | 1993–1995 (65 yr) | Fem-Pop (18%) | Balloon | 0%/8% (ITT) | 12 mo | 24 (27) | Clinical improvement | 74% (85%) | ~0.50 (NS) | C Medium
Vroegindeweij 1997^103^ 9354709 | 1993–1995 (65 yr) | Fem-Pop (18%) | Balloon | 0%/8% (ITT) | 12 mo | 24 (27) | Worsening | 9 (8) | 1.43 (NS) | C Medium
Zdanowski 1999^105^ 10811511 | nd (73 yr) | SFA (85%) | Balloon | 0%/0% (no) | 12 mo | 14 (15) | Clinical improvement | 10 (14) | 0.18 (NS) | C Medium
Retrospective
| | Ao-iliac | Mixed
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | 10 mo (median) | 34 (117) | Worsened SVS stage | nd | HR=3.7^B^ (P=0.02) | C High
| | | Balloon
Westcott 1998^117^ 9540904 | nd (56 yr) | Infrarenal aorta (12%) | Balloon | NA | 12 mo | 12 (13) | Improvement SVS | 11 (11) | 2.00 (NS) | C Narrow

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 8994707^57^, 9643685^95^, 10377079^55^, 15286319^96^.

D Stent outcome worse than PTA.

E Also 16672699^101^

F Estimated, Comparison of final values P=.02, but baseline dissimilar (Stent 2.6, PTA 2.0).

###### Minor amputations

Three RCTs on bare metal stents versus PTA (428 patients) reported relevant data. Results were reported over followup periods that ranged from about 6 months up to 8 years. The rates of minor amputations ranged from 0 to 4 percent in the stents arm and from 2 to 7 percent in the PTA arms. The summary OR for the minor amputations was 0.44 (95% CI 0.16, 1.26) favoring stenting, without evidence for between study heterogeneity. Subgroup analyses did not provide further insights. Sensitivity analyses resulted in very similar estimates.

Figure 10 Metaanalysis (Peto method) of odds ratio of major amputation for stents versus PTA

Appl: applicability (H, high; M, moderate; N, narrow); Ball: balloon expandable; CI: confidence interval; DIST: Dutch Iliac Stent Trial; mo: months; NE: not estimable; OR: odds ratio; PTA, percutaneous transluminal angioplasty; Qual: quality (A, good; B, fair; C, poor); Self: self-expanding; y: years

Shown is a forest plot (typical meta-analysis plot) that describes the odds ratio for major amputations in 5 trials (1 for iliac artery, 3 for femoral artery and 1 for tibial artery). Overall, the summary by the Peto method shows no statistically significant differences in the rates of major amputations among stents vs PTA. There is no evidence for statistical heterogeneity in these trials.

##### Summary

The comparative studies provide no evidence for statistically significant differences in the rates of major or minor amputations between stent placement versus PTA, regardless of diseased artery or stent type. The small number of studied patients and the rarity of major (and minor) amputations result in uncertain estimates regarding the relative likelihood of major and minor amputations across different interventions; even large effects in either direction cannot be excluded. The major caveat though, is that, on the whole, the studies did not evaluate patients at high risk of amputation prior to their vascular interventions.

#### Reinterventions

(Table 26, Figure 11)

##### Studies

Seven RCTs,40,56,93,94,98,99,102 one prospective study,107 and one retrospective study79 reported on reinterventions comparing stent versus PTA. Followup time in these studies ranged from 1 to 96 months. Methodological quality was rated good in four RCTs, fair in one RCT, and poor in two RCTs, the prospective study, and the retrospective study.

##### Outcome definitions

We initially defined as reintervention any repeated intervention on the initially treated lesion or vessel, irrespective of type (PTA, stent or bypass). However, all studies reported collectively all reinterventions on the treated leg rather than the treated lesion or vessel, with the exception of Schillinger 2007, where target vessel revascularizations were recorded. Studies did not stipulate explicit criteria on when to reintervene. Reinterventions were clinically driven (reported or implied).

##### Results

###### Iliac

One good quality RCT56 and a poor quality retrospective cohort study79 evaluated reintervention rates in patients with iliac disease. The two studies found similar results with nonsignificant risk differences of 4 or 5 percent, favoring PTA, and odds ratio of 1.3 with wide confidence intervals for reintervention with stent compared to PTA. The RCT used balloon stent; the retrospective study used either balloon or self-expanding stents.

###### Femoral popliteal

Across the six studies (five RCTs, one prospective study) reintervention rates among patients who received stents varied between 12 and 38 percent. The corresponding range among patients who received PTA (as a first treatment) was 0 to 54 percent. Risk differences ranged from 5 percent favoring stents to 38 percent favoring PTA (in a prospective nonrandomized study), but the differences were not statistically significant in any study.

Two good quality studies evaluated self-expanding stents and did not find a statistically significant difference in reintervention rate at 12^40^ and 24^102^ months. In metaanalysis, their summary OR was 0.72 (95% CI 0.37 – 1.40; Figure 11). One prospective nonrandomized study found a statistically significant increase in the risk of reintervention in the self-expanding stent group compared to PTA.107

Balloon stenting was compared to PTA in three RCTs, all of which found no significant difference in reintervention rates, with no consistency in direction of trends across the three trials. As shown in Figure 11, among the 3 trials using balloon expandable stents the summary OR was 1.07 (95% CI 0.51 – 2.23), with evidence for possible between study heterogeneity (P=0.12, I^2^=51%).

Table 25 Amputations: Stent versus PTA

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events Stent (Control) | RD, % (95% CI) | Quality Applicability
Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | Bold=Major Amputation Italic=Minor Amputation | | Quality Applicability
RCTs
| | Iliac | Balloon
Dutch Iliac Stent Trial 1998^96^ 15286319^C^ | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 6–8 yr | 143 (136) | 3 (8) | −3.8 (−8.4, 0.8) | A Medium
| | Fem-Pop | Self-expand
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | 61 (75) | 2 (0) | 3.3 (−1.2, 7.7) | C Medium
Schillinger 2007^102^ 17502568 D | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 12 mo | 51 (53) | 0 (0) | 0 | A High
Schillinger 2007^102^ 17502568 D | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 46 (52) | 0 (0) | 0 | A High
Schillinger 2007^102^ 17502568 D | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 46 (52) | 0 (1) | −1.9 (−5.7, 1.8) | A High
Schillinger 2007^102^ 17502568 D | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 46 (52) | 4 (9) | −3.8 (−8.8, 1.2) | A High
| | | Balloon
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 4 yr | 115 (112) | 1 (1) | 0 (−2.5, 2.4) | A Medium
| | Tibial | Balloon
Rand 2006^99^ 16252079 | nd (73 yr) | Tibial (Fontaine 3–4) | Balloon, treated^E^ | 3%/0% (no) | 5.5 mo (mean) | 24 (21) | 1 (0) | 4.2 (−3.8, 12) | C Medium
Rand 2006^99^ 16252079 | nd (73 yr) | Tibial (Fontaine 3–4) | Balloon, treated^E^ | 3%/0% (no) | 5.5 mo (mean) | 24 (21) | 1 (1) | −0.6 (−12, 12) | C Medium
Prospective
| | Tibial | Mixed
Bosiers 2006^106^ 16956473 | 2002–2005 (nd) | Tibial (nd) | Various F | Unclear | 6 mo | 158 [300 base] (37 [79 base]) | 1.4% (3.3%) | NS (survival analysis) | C High
Retrospective
| | Iliac | Mixed
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | 10 mo (median) | 34 (117) | nd (limb salvage) | NS | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 899470749, 9643685101, 1037707947, 1637158056.

D Also 16672699^101^.

E Carbofilm.

F Balloon-expandable (bare, passive-coated, and absorbable metal) or self-expanding.

Subgroup analyses by clinical and methodological characteristics of the studies did not offer additional insights.

###### Tibial

One poor quality, small RCT99 evaluated patients with tibial disease. The reintervention rates were low in both arms (4 percent with stent and 0 percent with PTA). This difference was not statistically significant. This study used a treated balloon stent.

##### Summary

The one good quality study on iliac artery intervention found no significant difference in rates of reinterventions comparing balloon-expandable stent with PTA. The two good quality studies of self-expanding stents in the femoral popliteal artery also did not find a statistically significant difference in the rates of reintervention when compared to PTA. The one poor quality study of treated balloon stent on tibial artery did not find a statistically significant difference. The body of evidence on reintervention rates is weak due to the heterogeneity of interventions and patients across studies, the generally small sizes of the studies, and the small number of studies. Furthermore, conclusions about reintervention rates will always be problematic due to the nature of the outcome (heterogeneous definitions and the interplay of clinician and patient preferences). The existing studies do not provide evidence of a difference in reintervention rates based on stenting versus PTA alone or planned PTA with conversion to stent placement.

Figure 11 Random effects model metaanalyses of odds ratio of reinterventions for stents versus PTA

Appl: applicability (H, high; M, medium; N, narrow); Ball: balloon expandable; CI: confidence interval; DIST: Dutch Iliac Stent Trial; mo: months; OR: odds ratio; PTA, percutaneous transluminal angioplasty; Qual: quality (A, good; B, fair; C, poor); Self: self expandable; y: years.

Shown is a forest plot (typical meta-analysis plot) that describes the odds ratio for reinterventions in 7 trials (1 for iliac artery, 5 for femoral artery, and 1 for tibial artery). None of the trials shows statistically significant results. Two subgroups were summarized with random effects metaanalysis. First, 3 of the trials on femoral arteries that used balloon expandable stents and the second pertained to 2 trials that used self-expanding stents. As was the case with the individual trials, their quantitative summaries were statistically nonsignificant. There is no evidence for statistical heterogeneity in the aforementioned metaanalyses.

Table 26 Reinterventions: Stent versus PTA

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events Stent (Control) | RD, % (95% CI) | OR (95% CI) | Quality Applicability
RCTs
| | Iliac | Balloon
Dutch Iliac Stent Trial 1998^56^ 16371580 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 6–8yr | 143 (136) | 46 (37) | 5.0 (−5.7, 16) | 1.27 (0.76, 2.1) | A Medium
| | Fem-Pop | Self-expand
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | ITT: 114 (115) | 17 (21) | −3.4 (−13, 6) | 0.78 (0.39, 1.58) | A Medium
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | On treatment: 127 (102) | 19 (19) | −3.7 (−14, 6) | 0.77 (0.38, 1.54) | A Medium
Schillinger 2007^102^ 17502568 D | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 46 (52) | 17 (28) | −17 (−36, 2.6) | 0.50 (0.22, 1.13) | A High
| | | Balloon
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 4 yr | 115 (112) | 14 (19) | −4.8 (−14, 4.4) | 0.68 (0.32, 1.43) | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | ~12 mo | 77 (77) | 21 (12) | 12 (−1.1, 25) | 2.0 (0.92, 4.5) | B High
Grimm 2001^98^ 9203369 | nd (70 yr) | SFA (79%) | Balloon | 0%/0% (nd) | 7/11 mo (mean E) | 30 (23) | 8 (7) | −3.8 (−28, 21) | 0.83 (0.25, 2.8) | C Medium
| | Tibial | Balloon
Rand 2006^99^ 16252079 | nd (72 yr) | Tibial (Fontaine 3–4) | Balloon, treated F | 3%/0% (no) | 5.5 mo (mean) | 24 (21) | 1 (0) | 4.2 (−3.8, 12) | -- | C Medium
Prospective
| | Fem-Pop | Self-expand
Do 1992^107^ 1423291 | nd | Fem-Pop (15%) | Self-expanding | NA | 12 mo | 26 (26) | 10 (0) | 38 (20, 57) | -- | C Narrow
Retrospective
| | Iliac | Mixed
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | 10 mo (median) | 34 (117) | 9 (26) | 4.2 (−12, 21) | 1.26 (0.52, 3.0) | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 8994707^57^, 9643685^95^, 10377079^55^, 15286319^96^.

D Also 16672699^101^.

E Stent / PTA arms.

F Carbofilm.

#### All-cause mortality

(Table 27, Figure 12)

Only mortality data from at least 6 months after the interventions are considered here. For 30-day mortality, which is a standard among interventionalists for procedure-related mortality, see page 107, under complications. For studies that did not state the timing of the reported mortality, we assumed that these were data from at least 6 months after the interventions.

##### Studies

Six RCTs reported on mortality rates comparing stent versus PTA.40,56,93,94,98,101,102 Followup time in these studies ranged from about 1 to 5.6 years, though one study did not define the timeframe.98 Four of the trials were rated to be of good quality for mortality outcomes with medium applicability in three and high applicability in one; there is one fair quality with high applicability and one poor quality with medium applicability.

Mean ages ranged from 58^56^ to 70^98^ years. Between 53^101^ and 72^56^ percent of patients were male. Diabetes was present in 10^56^ to 40^94^ percent of patients, a history of smoking in 44^101^ and 90^56^ percent, hypertension in 28^56^ to 91^101^ percent, hyperlipidemia in 25^56^ and 89^101^ percent, cardiac disease in 26^93^ and 71^101^ percent, and critical limb ischemia was present between 3^40^ and 79^98^ percent of patients (all in studies that reported the data). Judging by presence of cardiovascular risk factors and disease, the patients in the Dutch Iliac Stent Trial were at lower risk (except for their very high rate of smoking) and patients in Schillinger 2006^101^ and Grimm 2001^98^ were at relatively high risk.

##### Outcome definitions

All-cause mortality was the outcome assessed in all studies.

##### Results

Among four studies mortality rates at 1 year ranged between 2 and 16 percent after stent and 0 and 9 percent after PTA. One study had no deaths over about 30 months (although the duration being reported was unclear).98. One study had rates of death of 15 and 18 percent, respectively, at 3 years. The last study had similar mortality rates at 5.6 years: 15 and 16 percent, respectively. No study found a statistically different all-cause mortality rate at any time point. Risk differences ranged from −4.5 percent (favoring stent) at 12 months93 to 6.5 percent (favoring PTA) also at about 12 months.94

Figure 12 depicts the metaanalysis of the long term mortality (>30 days) in the 6 trials. On average, there was no statistically significant difference between stents and PTA (summary risk difference 1.6 percent, 95% CI −0.9, 4.1 percent). The metaanalysis was statistically homogeneous despite the clinical differences among studies. Subgroup analyses by clinical and methodological characteristics of the studies did not offer additional insights. Thus, the conclusions from these studies are similar for the three arterial sites and for self-expanding and balloon stents.

##### Summary

Though the data are limited and the studies were clinically heterogeneous in terms of arterial disease location, stent used, severity of patient disease, concomitant risk factors, duration of followup, methodological quality, and other factors, the studies consistently found no significant difference in mortality rates. However, the small number of studies and events may be masking true clinically important differences in mortality. Overall, while the studies do not support any difference in all-cause mortality, actual differences between the interventions cannot be ruled out.

Figure 12 Random effects model metaanalysis of risk difference of mortality in stents versus PTA trials (after 30 days)

Appl: applicability (H, high; M, medium; N, narrow); Ball: balloon expandable; CI: confidence interval; DIST: Dutch Iliac Stent Trial; nd: not described; PTA, percutaneous transluminal angioplasty; Qual: quality (A, good; B, fair; C, poor); RD, risk difference; Self: self expandable; y: years.

Shown is a forest plot (typical meta-analysis plot) that describes the risk difference for mortality in 6 trials (1 for iliac artery, 5 for femoral artery). Overall, the summary meta-analysis is nonsignificant regardless of whether a trial that has no events on either arm is added to the analyses or not. There is no evidence for statistical heterogeneity in these trials.

#### Walking Distance

(Table 28)

##### Studies

Four RCTs40,55,98,102 reported on changes in walking distance comparing stent with PTA. Followup time in these studies ranged from 12 to 24 months. Methodological quality was rated good in two studies and poor in two studies for this outcome. One high quality study had high applicability, the other three trials had medium applicability. Three studies evaluated patients with femoral popliteal lesions, though they differed greatly in their rates of critical limb ischemia (3, 13 and 79 percent). One study included patients with iliac disease who mostly did not have critical limb ischemia.

##### Outcome definitions

The Dutch Iliac Stent Trial measured walking distance during a 5-minute walking test with a maximum of 300 meters. Krankenberg 2007 and Schillinger 2007 measured maximum walking distance on a treadmill (2 and 3.2 km/hr, respectively, at 12° slope). Grimm 2001 reported the absolute claudicating distance on a treadmill.

Table 27 Mortality: Stent versus PTA

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover^B^ % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events Stent (Control) | RD, % (95% CI) | Quality Applicability
RCTs
| | Iliac | Balloon
Dutch Iliac Stent Trial 1998^56^ 16371580 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 5.6 yr | 143 (136) | 21 (22) | −1.5 (−10, 7.0) | A Medium
| | Fem-Pop | Self-expand
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (ITT) | 12 mo | 114 (115) | 4 (1) | 2.6 (−0.1, 6.4) | A Medium
Schillinger 2007^102^ 17502568 D | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 12 mo | 51 (53) | 1 (0) | −2.0 (−1.8, 5.8) | A High
| | | Balloon
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21 %) | Balloon | 13%/1% (ITT) | 1 yr | 115 (112) | 3% (7%) [Survival analysis] | −4.5 (−10, 1.0) | A Medium
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21 %) | Balloon | 13%/1% (ITT) | 3 yr | 115 (112) | 15% (18%) [Survival analysis] | −3.1 (−13, 6.5) [NS, 4 yr overall] | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | ~12 mo | 77 (77) | 12 (7) | 6.5 (−3.8, 17) | B High
Grimm 2001^98^ 9203369 | nd (70 yr) | SFA (79%) | Balloon | 0%/0% (nd) | Unclear | 30 (23) | 0 (0) | 0 | C Medium

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 8994707^57^, 9643685^95^, 10377079^55^, 15286319^96^.

D Also 16672699^101^.

##### Results

The Dutch Iliac Stent Trial analyzed 279 patients with iliac artery intervention and did not find a statistically significant difference in changes in walking distance comparing a balloon stent with PTA (where 43 percent of patients were converted to have a stent) at 24 months.55 Krankenberg 2007 analyzed 136 patients with superficial femoral artery disease and found a statistically significant greater maximal walking distance among patients assigned to self-expanding stenting (P=.03); however, this outcome was poorly reported and the actual average difference in walking distance between the two groups is unclear. Schillinger 2007 analyzed 104 patients with superficial femoral artery intervention and found that patients in the stent group walked significantly farther on a treadmill than patients in the PTA group at 12 months (P=0.04), but not at 24 months (P=0.12).102 Grimm 2001 analyzed 53 patients with femoral popliteal artery intervention and reported no statistically significant difference in the absolute claudicating distance between the stent and the PTA group; the time when the walking distance was assessed was not reported.98

##### Summary

Only four trials comparing stent with PTA reported changes in walking distance. Comparing stent with PTA, one good quality trial on iliac artery intervention did not find a significant difference in walking distance (with balloon stents); two trials (one good and one poor quality) on femoral artery intervention reported a statistically significant increase in walking distance at 12 months, but not at 24 months (in one trial) with a self-expanding stents. These limited data are insufficient to provide evidence of a clear benefit of stenting over PTA; though there is a suggestion that self-expanding stent placement may result in increased maximal walking distance, compared to PTA alone (or planned PTA with conversion to stenting) in patients with superficial femoral artery disease.

#### Ankle-brachial Index (ABI)

(Table 29, Figure 13)

##### Studies

Eight RCTs,40,56,93,98,100,103,105 one prospective108 and three retrospective studies113,115,117 reported on changes in ankle-brachial index (ABI) comparing stent versus PTA. Followup times in these studies ranged from 6 months up to 8 years. Methodological quality was rated good in two RCTs, fair in one RCT, and poor in five RCTs, one prospective, and three retrospective studies for this outcome. Only one RCT had high applicability; one of the RCTs and two retrospective studies had narrow applicability; the rest had medium applicability.

One RCT and the prospective study included patients with iliac lesions, and one retrospective study evaluated patients with infrarenal lesions; the other studies treated femoral popliteal lesions. Most studies had relatively few patients with critical limb ischemia, though three studies had critical limb ischemia rates over 50 percent.

##### Outcome definitions

ABI is a standard measurement used to diagnose and evaluate lower extremity PAD.26 With a sphygmomanometer and a Doppler instrument the systolic pressure of the posterior tibial and dorsalis pedis arteries of the affected leg are measured. These pressures are then normalized (divided by) the brachial (arm) pressure. The test is usually performed with the patient at rest (as was done in all but one study100). The typical cut-off for diagnosing PAD is ABI≤0.90 at rest. Of note, patients with calcified vasculature due to diseases such as diabetes and chronic kidney disease will have falsely elevated ABIs. These patients should be tested with other methods. None of the studies reported excluding these patients from this analysis.

Table 28 Walking distance: Stent versus PTA

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover^B^, % (ITT?) | Time | N Stent (Control) | Baseline, m Stent (Control) | Final, m Stent (Control) | Net Change (95% CI) | Quality Applicability
RCTs
| | Iliac | Balloon
Dutch Iliac Stent Trial 1998^56^ 16371580 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 12 mo | 143 (136) | 190 D (204) | 261 (263) | 12 (−9, 33) E | A Medium
Dutch Iliac Stent Trial 1998^56^ 16371580 C | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 24 mo | 143 (136) | 190 D (204) | 258 (255) | 17 (−4, 38) E | A Medium
| | Fem-Pop | Self-expand
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (ITT) | 12 mo | 61 (75) | ~133, median (~130) F | 185 (150) | P=.03 | C Medium
Schillinger 2007^102^ 17502568 G | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 12 mo | 51 (53) | 92 H, median (87) | 375, mean (250) | P=0.04 J | A High
Schillinger 2007^102^ 17502568 G | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 46 (52) | 88, median (86) | 302, median (196) | P=0.12 J | A High
| | | Balloon
Grimm 2001^98^ 9203369 | nd (70 yr) | SFA (79%) | Balloon | 0%/0% (nd) | Unclear | 30 (23) | 166 K (150) | 384 (467) | −99 (−272, 74)^E^ | C Medium

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 899470749, 9643685101, 1037707947, 15286319102.

D Test not described.

E Estimated from reported data.

F Approximated from reported data. At baseline, 97 of 121 stent patients had walking distance measured: median 110 m; only 61 had both baseline and final test. 99 of 123 PTA patients had median walking distance of 100 m; only 75 had both baseline and final test.

G Also 1667269956.

H Maximal distance on treadmill; assumed to be 0 m in patients with critical limb ischemia; 3.2 km/hr and 12° incline.

J Comparison of final values.

K Walking distance to claudication.

The test can also be performed after exercise, as was done in two trials.93,100 The post-exercise pressure may be lower than the resting pressure due to the effect of the increased blood flow requirements to muscles induced by exercise. This is particularly evident in stenoses which may be subcritical at rest, but become critical with exercise. Alternatively, the post exercise pressure may reflect the degree of collateral vessel formation around an occluded vessel.

##### Results

###### Iliac

Two studies evaluated resting ABI in patients with iliac lesions. The (high quality) Dutch Iliac Stent Trial found no significant difference in ABI 1, 2, or 6 to 8 years after the procedures regardless of whether patients were assigned to primary stenting or PTA. The prospective study (Schillinger 2002) and the retrospective study (Westcott 1998^117^) also found no significant difference. The trial and the retrospective study used balloon expandable stents. The prospective comparative study did not report stent type, but based on the publication date, it is likely that they too used balloon expandable stents.

###### Femoral popliteal

Three trials and one retrospective study used self-expanding stents. The high quality trial among them (Schillinger 2006) found that ABI at 12 months was significantly higher (better) among patients assigned to stent; at 24 months ABIs were still higher after stent, but the difference was smaller and not statistically significant. Saxon 2003 and the retrospective analysis performed by Cho 2003 also found statistically significantly better ABI after self-expanding stent placement at both 6, and at 24 months in the trial. The remaining trial (Krankenberg 2007) found no significant difference in ABI at 12 months.

Four of the trials reported on comparisons of balloon stents versus PTA on ABI. One retrospective study (Pozzi Mucelli 2003) analyzed a cohort of patients for whom both balloon and self-expanding stents were used. Three out of four of the trials and the retrospective analysis found no difference in ABI at 12 months (or at an undefined time). Only one poor quality trial (Grimm 2001) found a significant improvement in ABI after balloon stenting compared to PTA alone.

The results of the few trials that provided sufficient data for graphing are presented in the Figure 13. Notably, the RCT of patients with iliac lesions found no difference in change in ABI between interventions, compared to the trials of femoral popliteal lesions. This difference may be due to intrinsic differences based on anatomy (iliac versus femoral disease) or may be related to the very high crossover rate in the Dutch Iliac Stent Trial, such that 43 percent of patients assigned to PTA had secondary stenting. However, there was a 32 percent crossover in the Schillinger 2006 trial. The difference may also be spurious, given that three trials of femoral popliteal disease with no significant differences in resting ABI (and a fourth trial that reported baseline resting ABI, but results only for exercise ABI) did not report adequate data for metaanalysis. Given all these issues, and the small number of similar studies, metaanalysis was not performed.

Figure 13 Forest plot of net change in ABI in stents versus PTA trials (no metaanalysis performed)

ABI: ankle-brachial index; Appl: applicability (H, high; M, medium: N: narrow); Ball: Balloon expandable; CI: confidence interval; DIST: Dutch Iliac Stent Trial; nd: not described; PTA, percutaneous transluminal angioplasty; Qual: Quality (A, good; B, fair; C, poor); Self: self-expanding; y: years

Shown is a forest plot that describes the net difference in ABI in 4 trials (1 for iliac artery, 3 for femoral artery). These trials were not metaanalyzed to give an overall summary. Overall, the 3 trials on femoral artery favored stents over balloon angioplasty with respect to ABI; in all three the net difference in the change in the ABI from baseline was statistically significant. In contrast, a single trial on iliac arteries showed no evidence for a net change in the ABI at 1, 2 or 8 years of follow up.

##### Summary

The evidence on the effect of balloon expandable stents on iliac disease are sparse, but suggest no difference in ABI, either short or long-term, based on whether stent use or PTA were planned. However, this conclusion is based largely on a trial in which almost half the patients with planned PTA were converted to stent placement. Among patients with superficial femoral artery disease, the evidence suggests, though is not conclusive, that patients assigned to self-expanding stents have better short term (6 to 12 month) ABI than those assigned to PTA, with possible better longer term results also. However, the trials that evaluated balloon expanded stents failed to find a benefit in ABI for stent compared to PTA.

Table 29 Ankle brachial index (ABI): Stent versus PTA

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | N Stent (Control) | Baseline Stent (Control) | Final Stent (Control) | Net Change (95% CI) | Quality Applicability
RCTs
| | Iliac | Balloon
Dutch Iliac Stent Trial 2006^56^ 16371580^C^ | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 12 mo | 118 [135 base] 112 [124 base] | 0.75 (0.77) | 0.94 (0.98) | −0.02 (−0.07, 0.03) | A medium
Dutch Iliac Stent Trial 2006^56^ 16371580^C^ | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 24 mo | 107 99 | 0.75 (0.77) | 0.97 (1.00) | −0.01 (−0.08, 0.06) | A medium
Dutch Iliac Stent Trial 2006^56^ 16371580^C^ | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | 6–8 yr | 101 85 | 0.75 (0.77) | 0.90 (0.96) | −0.04 (−0.09, 0.01) | A medium
| | Fern-Pop | Self-expand
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (ITT) | 12 mo | 61 (75) | 0.68^D^ median (0.72) | +0.21^E^ median (+0.15) | NS | C Medium
Schillinger 2007^102^ 17502568^F^ | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 12 mo | 51 (53) | 0.57 (0.54) | 0.84 (0.67) | 0.14 (P=0.03)^G^ | A High
Schillinger 2007^102^ 17502568^F^ | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 24 mo | 51 (53) | 0.58 (0.54) | 0.88 (0.77) | 0.06 (P=0.09)^G^ | A High
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Covered, self-expanding | 6%/0% (ITT) | 6 mo | 15 (13) | Exercise: 0.36 (0.43) | 0.80 (0.50) | 0.37 (0.23, 0.51) | C Narrow
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Covered, self-expanding | 6%/0% (ITT) | 24 mo | 15 (13) | Exercise: 0.36 (0.43) | 0.86 (0.67) | 0.26 (0.11, 0.40) | C Narrow
| | | Balloon
Becquemin 2003^93^ 10069906 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | ≤12 mo | 115 (112) | Rest: 0.74 (0.72) | nd | NS | C Medium
Becquemin 2003^93^ 10069906 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | ≤12 mo | 115 (112) | Post-Exercise: 0.52 (0.48) | nd | NS | C Medium
Grimm 2001^98^ 9203369 | nd (70 yr) | SFA (79%) | Balloon | 0%/0% (nd) | Unclear | 30 (23) | 0.47 (0.62) | 0.91 (0.85) | 0.21 (0.05, 0.37)^H^ | C Medium
Vroegindeweij 1997^103^ 9354709 | 1993–1995 (65 yr) | Fern-Pop (18%) | Balloon | 0%/8% (ITT) | 12 mo | 24 (27) | nd | 0.78 (0.81) | (NS)^G^ | B Medium
Zdanowski 1999^105^ 10811511 | nd (73 yr) | SFA (85%) | Balloon | 0%/0% (no) | 12 mo | 15 (17) | 0.48 (0.42) median | 6 w/ABI ↑≥0.10 (8) | OR=0.63 (0.13, 3.1) | C Medium
Prospective
| | Iliac | No Data
Schillinger 2002^108^ 12083502 | nd (61 yr) | Iliac (Fontaine lla-4) | nd | NA | 6 mo | 63 (74) | 0.55 (0.51) median | 0.69 (0.73) median | [−0.07]^J^ (NS)^G^ | C Medium
Retrospective
| | Aorto-iliac | Balloon
Westcott 1998^117^ 9540904 | nd (56 yr) | Infrarenal aorta (12%) | Balloon | NA | 12 mo | 9 (7) | 0.61 (0.65) | 0.85 (0.95) | −0.06 (−0.28, 0.16)^H^ | C Narrow
| | Fem-Pop | Self-expand
Cho 2003^113^ 12668846 | 1999–2002 (71 yr) | SFA (0%) | Self-expanding | NA | 6 mo | 14 (26) | 0.61 (0.63) | 0.93 (0.83) | +0.12 (+0.05, +0.19)^H,K^ | C Narrow
| | | Mixed
Pozzi Mucelli 2003^115^ 12835627 | 1995–2001 (67 yr) | Fem-Pop (54%) | Balloon or self-expanding | NA | nd | 23 (86) | nd | 0.96 (0.91) | (NS)^G^ | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 899470749, 9643685101, 1037707947, 15286319102.

D In 97 (99) patients at baseline.

E Change from baseline in analyzed patients.

F Also 1667269956.

G Comparison of final values.

H Estimated from reported data.

J Net difference of median values.

K However analysis done by authors (statistical significance of final values) was nonsignificant.

#### Miscellaneous outcomes

Two RCTs that compared stent to PTA reported other long-term clinical outcomes that were not reported by other studies.

##### Other vascular events

Becquemin 2003^93^ followed patients for up to 4 years after being randomized to Palmaz stent or PTA; 115 received stents and 112 had PTA, 13 percent of whom had secondary stent placement.

A Kaplan-Meier analysis of “survival free of a critical limb ischemia event” (rest pain or tissue necrosis) in the treated leg statistically significantly favored PTA over stent (P=0.02). An approximation of the hazard ratio drawn from the reported figure was 0.65. Notably, this finding was consistent with similar results for clinical status (Table 24), although rates of mortality, amputation, and vascular procedures did not significantly differ.

Acute ischemic events were more common among those with primary stents (3/115) than PTA (0/112), though this difference is not statistically significant (RD 2.6 (95% CI −0.3, 5.5) percent).

“Trash foot,” distal embolization of microscopic atherosclerotic debris, was also more common after stent (4/115) than PTA (1/112), which again was not statistically significant (OR 4.0 (95% CI 0.44, 36); RD 2.6 (−1.2, 6.4) percent).

At this point it is worth noting that Becquemin 2003^93^ came to the unique conclusion among the trials and other studies that patients had worse outcomes after primary stenting than after primary PTA (with secondary stenting in 13 percent of patients). The study was relatively large, and of good methodological quality and medium applicability. The interventions were performed about a decade ago. The study was not substantially different than other trials of stents versus PTA of femoral popliteal arteries, with one important exception. Almost uniquely, the trial reported using independent, blinded outcome assessors. In addition to the vascular findings above, this trial found that clinical status was also significantly worse in patients who received primary stents. However, no significant differences were found in amputation, reintervention, or mortality rates, or in ABI. The authors describe that intra-stent hyperplasia was responsible for most late failures. The occurrence of hyperplasia peaked within the first 18 months and was stable over longer terms.

##### Quality of life

The Dutch Iliac Stent Trial55 compared primary Palmaz stent placement to PTA with secondary stent placement in 43 percent of patients. Quality of life was assessed with the SF-36 health survey118 at 1, 2, and 5 years. Overall, health-related quality of life improved equally for both groups of patients across quality of life domains and over time. No significant differences were found.

#### Overall summary of stent versus PTA RCTs

(Table 30)

Ten trials with 1190 patients met criteria; seven used balloon expandable stents and three self-expandable stents. Eight stent trials addressed femoral popliteal disease and the change to self-expandable nitinol stents appeared to extend the extent of the atherosclerotic lesion treated. Balloon-expandable stents of the Palmaz type were limited to treating lesions of less than 5 cm (e.g., 2.23 cm mean and 25% occlusions in Cejna 2001), while self-expandable stents permitted treatment of longer lesions and a greater proportion of occlusions (e.g., 10.1 cm mean in Schillinger 2006 with 40% occlusions; 5.3 cm mean and 45% occlusions in Krankenberg 2007). One trial used treated stents and one used covered stents. Eight included patients with femoral popliteal disease, one iliac, and one tibial. Followup was 6 to 96 months. Three trials were rated good, one fair, and five poor quality.

Overall, the trials found no statistically significant difference in clinical outcomes between primary stent and PTA. When analyzed by specific segment treated the femoral popliteal RCTs did demonstrate some subtle differences. Limited metaanalyses of major amputations (OR 0.76, 95% CI 0.28, 2.05), reinterventions (OR 1.07, 95% CI 0.51, 2.23 for balloon expandable and 0.72, 95% CI 0.37, 1.40 for self-expanding stents in the femoral artery), and mortality (RD 2 percent, 95% CI −1, 4) found no significant differences. An important caveat to the amputation outcome, though, is that on the patients included in the studies mostly did not have chronic limb ischemia and therefore were not at substantial risk of amputation. One larger good quality trial of patients with femoral popliteal lesions (Becquemin 2003^93^) found that clinical status and survival free of critical limb ischemia favored primary PTA over primary stenting, which was ascribed to intrastent hyperplasia. The other good quality trial of femoral popliteal lesions (Schillinger 2002^108^) found that clinical status and survival free of critical limb ischemia favored primary PTA over primary stenting, which was also ascribed to intrastent hyperplasia. Becquemin 2003 demonstrated a higher proportion of adverse “vascular local events” in the PTA + stent group. With the newer nitinol stent Schillinger 2006 observed no difference in worsening by two Rutherford stages, thrombosis or need for ipsilateral reintervention between the PTA group and the stent groups, despite improved maximal walking distance and ABIs in the stent group. This study, however, was marked by a relatively high crossover from the PTA group to the stent group, due to the need for secondary stenting. The more recent study of Krankenberg 2007 similarly showed no difference in improved Rutherford stages and ABIs between the two groups, but an advantage in maximal walking distance for the stent group.

The Dutch Iliac Stent Trial was the only RCT of patients with aorto-iliac disease. It compared selective stenting in one arm (for a post-PTA mean pressure gradient of 10 mm Hg) to primary stenting. In the selective stenting group 43 percent of patients required stents. No differences in quality of life, 3 month ABIs, requirement for reintervention were seen for the two groups, but persistence of PAD symptoms were higher at late followup in the primary stenting group.

The available trials do not provide evidence that primary stenting results in better clinical outcomes than PTA. Except for one trial, studies found similar results despite heterogeneity in patients, disease anatomy, interventions, and study design. However, the trials were generally small, with few events occurring during followup, so the trials do not exclude the possibility of even large differences in effect.

Table 30 Study designs and clinical outcome rates

Study | Artery | Stent^*^ | Xover | Quality | N | Clinical Outcomes (Times outcomes evaluated)
Study | Artery | Stent^*^ | Xover | Quality | N | Clinical Status | Major Amputation | Reintervention | Mortality | Walking distance | | Quality of Life
| Iliac | Balloon
Dutch Iliac Stent Trial 1998 | Iliac | Bb | 43% | Good | 279 | NS 1–8 yr | NS 6–8 yr | NS 6–8 yr | NS 5.6 yr | NS 1–2 yr | | NS 1–5 yr
| Fem-Pop | Self-exp
Krankenberg 2007 | SFA | Sb | 11% | Good/ Poor | 244 | NS 1 yr | | NS 1 yr | NS 1 yr | ~+32 m^‡^ 1 yr
Schillinger 2006 | SFA | Sb | 32% | Good | 104 | NS 1–2 yr | NS 1–2 yr | NS 2yr | NS 1 yr | +125 m^‡^ 1 yr | NS 2 yr
Saxon 2003 | SFA | Sc | 6% | Poor | 28 | NS 0.5–2 yr
| | Balloon
Becquemin 2003 | SFA | Bb | 13% | Good | 227 | OR2^†^ 4yr | NS 4yr | NS 4yr | NS 4yr
Cejna 2001 | FP | Bb | 13% | Fair | 154 | NS 1 yr | | NS 1 yr | NS 1 yr
Grimm 2001 | SFA | Bb | 0% | Poor | 53 | | | NS <1 yr | NS nd | NS nd
Vroegindeweij 1997 | FP | Bb | 0% | Poor | 51 | NS 1 yr
Zdanowski 1999 | SFA | Bb | 0% | Poor | 29 | NS 1 yr
| Tibial | Balloon
Rand 2006 | Tibial | Bt | 3% | Poor | 45 | | NS 0.5 yr | NS 0.5 yr
| | Metaanalysis (95% CI) [No. trials in metaanalysis] | | | | -- | OR 0.76 (0.28, 2.05) [5 trials] | --^#^ | RD2% (−1, 4%) [6 trials] | -- | | --

CI, confidence interval; FP, femoral popliteal; nd, no data; NS, nonsignificant; OR, odds ratio; SFA, superficial femoral artery; Xover, crossover; yr, year

* Stent type used: B, balloon; S, self-expanding; b, bare; c, covered; t, treated.

† Favor PTA; also significant differences in survival free of a chronic limb ischemia event (HR ~0.65, P=.02).

‡ Difference in walking distance at 12 mo, favor stent.

# Limited metaanalyses among 5 trials in the femoral popliteal arteries: OR 1.07 (0.51, 2.23) [3 trials; balloon expandable bare stents] and OR 0.72 (0.37, 1.40) [2 trials; self-expanding covered stents)

### 3.4.2 Stent versus Bypass

#### Description of studies

(Tables 31 & 32)

One trial76 and one retrospective study111 compared patients who had stent insertion with patients who had bypass.

In the trial, a nitinol (self-expanding) stent exoskeleton supporting an ultrathin expanded ePTFE graft was compared to femoral popliteal bypass with either an ePTFE or Dacron conduit. The trial included 86 patients with superficial femoral artery lesions; 50 limbs in 40 patients were treated with stent versus 50 limbs in 46 patients which were treated with bypass. These patients had adequate runoff and were without significant aorto-iliac disease. The median followup was 18 months. After treatment patients took aspirin and clopidogrel for at least 3 months (or continued on warfarin instead of clopidogrel). Patients receiving stents were statistically significantly older (72 versus 67 years); patients ranged from 40 to 86 years; 39 percent had diabetes, 57 percent had a smoking history, 84 percent had hypertension, 52 percent had hyperlipidemia, and 41 percent had concomitant cardiac disease. Most patients had claudication (72 percent), 14 percent had rest pain, and 14 percent had tissue necrosis. The TASC classification of the patients was also reported: A 3 percent; B 14 percent; C 68 percent; D 15 percent. No data were reported regarding blinding, randomization method, allocation concealment, or use of intention-to-treat analyses. The methodological quality of the study was fair and applicability was rated medium.

In the retrospective study on patients with aorto-iliac disease, 65 patients who received stents (either Palmaz or Wallstent) were compared with 54 patients who received bypass. The mean followup was 22 months. The pattern of aorto-iliac disease was different between the two groups; more patients in the bypass group had category 4 (SVS) lesions, compared to patients in the stent group. The methodological quality of the study was poor and applicability was rated high.

##### Results

###### Randomized Controlled Trial

[underlined: Clinical status:] An improvement in SVS classification was reported in 100 percent of the limbs in the stent group compared to 92 percent of the limbs in the bypass group. The overall mean improvement was 2.4 grades in both groups.

[underlined: Amputation:] Limb salvage at 12 months was 98 percent for the stent group and 90 percent for the bypass group (P=0.09).

[underlined: Mortality:] The study reported four patients died during the study period; the result was not stratified by group assignment. The study reported that these patients died from causes unrelated to their infrainguinal atherosclerotic disease.

[underlined: Ankle-brachial index:] At 12 months, the mean improvement in ABI was 0.23 for the stent group versus 0.37 for the bypass group (P=0.11).

###### Retrospective Study

[underlined: Mortality:] No perioperative death was reported in the stent group; one perioperative death (1.9 percent) (myocardial infarction) was reported in the bypass group. At the time of followup, 3 (4.6 percent) other patients in the stent group and 2 (3.7 percent) other patients in the bypass group died. Two patients had myocardial infarction, one had respiratory failure, and two had metastatic cancer.

[underlined: Ankle-brachial index:] The mean improvement in ABI was 0.40 in both groups.

##### Summary

One fair quality RCT and one poorly reported retrospective study compared stent with bypass. These studies did not find any statistically significant differences between the use of stent or bypass in the treatment of femoral popliteal disease in terms of clinical improvement, limb salvage rate, mortality, or ABI in an average followup of 18 and 22 months.

Table 31 Amputation and mortality: Stent versus

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Outcome | Time | No. Analyzed Stent (Control) | No. Events Stent (Control) | RD, % (95% CI) | Quality Applicability
RCT
| | Fem-Pop | Self-expand
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fern-Pop (28%) | Self-expanding, covered | 0%/0% (nd) | Clinical status, no improvement | nd | 50 limbs (50) | 0 (4) | −8.0 (−16,−0.5) | B Medium
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fern-Pop (28%) | Self-expanding, covered | 0%/0% (nd) | Major amputation | 12 mo | 50 limbs (50) | 1 (5) | −8.0 (−17, 1.2) | B Medium
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fern-Pop (28%) | Self-expanding, covered | 0%/0% (nd) | Mortality | nd | 40 (50) | 4 (4) | 2.0 (−10, 14) | B Medium
Retrospective
| | Aorto-iliac | Balloon
Ballard 1998^111^ 9685135 | 1992–1996 (65 yr) | Aorto-iliac (85%) | Balloon | NA | Mortality | 22 mo | 65 (54) | 3 (2) | 0.9 (−6.3, 8.1) | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

Table 32 ABI: Stent versus Bypass

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | Baseline Stent (Control) | Final Stent (Control) | Net Change (95% CI) | Quality Applicability
RCTs
| | Fern-Pop | Self-expand
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fern-Pop (27%) | Self-expanding, covered | 0%/0% (nd) | 12 mo | 40 (46) | 0.57 (0.46) | 0.80 (0.83) | −0.14 (−0.31, 0.03) | B Medium
Retrospective
| | Aorto-iliac | Balloon
Ballard 1998^111^ 9685135 | 1992–1996 (65 yr) | Aorto-iliac (70%) | Balloon | NA | “Early” | 65 (54) | nd | −0.4 overall | ~0 (NS, implied) | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

### 3.4.3 Stent versus Stent

#### Bare stent versus drug-eluting stent

(Tables 33 & 34)

One trial70,97,119 and one prospective study109 compared patients who had bare stent insertion with patients who had drug-eluting stent insertion.

The trial compared 47 patients who received a sirolimus coated nitinol (self-expanding) stent with 46 patients who received a bare nitinol stent. All patients had chronic limb ischemia and TASC C superficial femoral artery disease. Mean followup was 24 months. Patients were treated with aspirin for at least 12 months and another antiplatelet drug for at least 3 or 4 weeks. The patients were on average 66 years old (range 38 to 84); 72 percent were male, 39 percent had diabetes, 38 percent were current smokers, 69 percent had hypertension, 63 percent had hyperlipidemia, and 44 percent had concurrent cardiac disease. Half the patients were in SVS classes 1 or 2, half 3 or 4. The authors noted that “the patients who received sirolimus-eluting stents were generally at greater risk of restenosis or complications than the control group”; 57 percent of patients with drug-eluting stents had moderate or severe calcification of their lesions while 35 percent of those with bare stents had calcification (P=0.03). No data were reported regarding blinding, randomization method, allocation concealment, or use of intention-to-treat analyses. The methodological quality of the study was rated fair and the applicability was rated medium. However, the quality of the ABI results was rated poor because the baseline data were not reported.

The prospective study reported 6 months outcomes on 29 patients who received sirolimus-eluting stents compared with 29 patients who received balloon-expandable bare metal stents for bailout after suboptimal PTA in the infrapopliteal arteries. All patients had chronic limb ischemia. More patients had symptomatic cardiac and carotid diseases in the sirolimus group, compared to the bare metal group (ASA 3, 24 versus 7 percent, P=0.03). The methodological quality of the study was poor and applicability was rated medium.

##### Results

[underlined: Clinical status:] In the trial, both groups of patients showed a sustained improvement in SVS classification over 24 months, any difference between groups was not reported. In the prospective study, the proportion of patients without rest pain at 6 months was 82 percent in the bare stent group versus 92 percent in the sirolimus group (P=0.12).

[underlined: Reinterventions:] In the trial, the target vessel revascularization at 24 months was 22 percent in the bare stent group versus 13 percent in the sirolimus group (difference NS). In the prospective study, target lesion revascularization was 17 percent in the bare stent group versus 4 percent in the sirolimus group (P=0.02). Also, target vessel revascularization was 24 percent in the bare stent group versus 18 percent in the sirolimus group (P=0.32).

[underlined: Amputation:] In the trial at 24 months followup, no patients in either group had amputations. There was no major amputation reported in the prospective study; minor amputation rates were 17 percent in the bare stent group versus 3 percent in the sirolimus group (P=0.04).

[underlined: Mortality:] In the trial, 2 patients (1 complication of coronary bypass, 1 cardiac failure) died in the bare stent group versus 7 patients (1 stroke, 1 pulmonary emboli, 1 cancer, 2 cardiac disease, 2 natural causes) died in the sirolimus group (difference NS). The 6-month mortality in the prospective study was 2 patients in the bare stent group versus 3 patients in the sirolimus group (P=0.32). All patients died from cardiac causes.

[underlined: ABI:] In the trial, ABI remained increased in both groups for 24 months; there was no statistically significant difference between groups (0.84, bare stent versus 0.90, sirolimus; P=0.13). In the prospective study, ABI at 6 months was 0.90 in the bare stent group versus 0.96 in the sirolimus group (P=0.10).

##### Summary

One fair quality trial comparing bare stent with sirolimus stent did not find any statistically significant difference in clinical status, reintervention rates, amputation rates, mortality, and ABI outcomes at 24 months followup. One poor quality prospective study found that at 6-month followup, the target lesion reintervention rate and minor amputation rate were lower in the sirolimus group compared to the bare stent group. Baseline characteristics in this study were not entirely comparable as the sirolimus group had more patients with symptomatic cardiac and carotid diseases than the bare stent group.

#### Stent with brachytherapy versus stent

(Tables 35 & 36)

One trial evaluated the effectiveness of vascular brachytherapy with iridium 192 (^192^Ir) after femoral popliteal stent implantation.104 This trial evaluated the effect of adding brachytherapy to stent placement; but it did not principally evaluate the relative effect of stents. All patients were at least 50 years old, had a history of claudication (SVS 2 or 3) for more than 3 months or critical limb ischemia, aorto-iliac vessels with adequate inflow, lesion located 10 cm or more from the femoral bifurcation, and residual stenosis greater than 30 percent, severe dissection, or both after PTA and stent implantation. The trial compared 42 patients with ^192^Ir brachytherapy to 46 patients without. Patients had a mean age of 68 years; 65 percent were male, 39 percent had diabetes, 39 percent had a smoking history, 76 percent had hypertension, and 72 percent had hyperlipidemia. Women were significantly older than men in both groups (stent and ^192^Ir: 72 versus 65, P=0.05; stent only: 72 versus 66, P=0.04). An ^192^Ir source delivered a mean activity of 200 GBq (range, 150–366 GBq). Patients who had stents only received sham treatment. Followup was at 12 months. This was a double-blinded trial; patients and investigators in the followup examinations were blinded to the patients’ group assignments. Randomization method and allocation concealment were not adequately reported. The analysis was effectively intention-to-treat as there were no crossovers or dropouts, except that fewer than half the patients had followup walking distance or ABI measured. Furthermore, mortality data were incompletely reported. Overall, the methodological quality of the study was rated fair, but ABI and walking distance data were rated poor, because a large proportion of patients did not have post-procedure testing. The study had narrow applicability.

##### Results

[underlined: Clinical status:] In the trial, clinical success was defined as immediate improvement by at least one clinical category of SVS classification; clinical patency was defined as sustained clinical success without further intervention. At 12 months, the clinical patency was 62 percent in the ^192^Ir group versus 54 percent in the stent only group (difference NS). [underlined: Reinterventions:] In the trial, the target vessel revascularization at 6 months was 17 percent in the ^192^Ir group versus 32 percent in the stent only (difference NS).

[underlined: Mortality:] In the trial, 4 patients died of causes unrelated to treatment after 12 months. One patient died of recurrence of disease in the segment treated with a stent. The report did not provide details as to which randomized groups these patients belonged to.

[underlined: ABI:] At 12 months, ABI was 0.91 in the ^192^Ir group versus 0.71 in the stent only group (difference NS), although only 49 percent of the limbs (compared to before intervention) could be evaluated.

[underlined: Walking Distance:] At 12 months, walking distance was ABI was 384±294 meters in the ^192^Ir group versus 329±216 meters in the stent only group (difference NS), although only 41 percent of the patients (compared to before intervention) could be evaluated.

##### Summary

Limited data from one small trial comparing stenting and the followup use of ^192^Ir brachytherapy to stenting only without the use of brachytherapy did not find any statistically significant difference in clinical status, ABI, and walking distance outcomes at 12 months followup.

Table 33 Clinical outcomes: Drug-eluting stent versus bare stent

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Outcome | Time | No. Analyzed Drug (Bare) | Events | Result | Quality Applicability
RCT
| | Fem-Pop
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | Clinical status (SVS 3–4) | 18 mo | 39 (38) | 1 (1) | OR 0.97 (NS) | B Medium
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | Clinical status (SVS 3–4) | 24 mo | 34 (38) | 2 (3) | OR 0.73 (NS) | B Medium
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | Major Amputation | 24 mo | 47 (46) | 0 (0) | RD 0 | B Medium
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | Mortality | 24 mo | 47 (46) | 7 (2) | RD 11 (−1.2, 22) | B Medium
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | Reintervention | 12 mo | 47 (46) | 4 (6) | RD −4.5 (−17, 8.1) | B Medium
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | Reintervention | 24 mo | 47 (46) | 6 (10) | RD −9.0 (−24, 6.3) | B Medium
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Clinical status (Symptom relief) | 6 mo | 26 (27) | 24 (22) | OR 2.7 (NS) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Major Amputation | 6 mo | 29 (29) | 0 (0) | RD 0 | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Major Amputation | 12 mo | 29 (29) | 1 (0) | RD 3 (−6, 13) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Minor Amputation | 6 mo | 29 (29) | 1 (5) | RD −14 (−29, 1.5) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Minor Amputation | 12 mo | 29 (29) | 3 (5) | RD −7 (−25, 11) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Mortality | 6 mo | 29 (29) | 3 (2) | RD 3.4 (−11, 18) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Mortality | 12 mo | 29 (29) | 4 (3) | RD 3.4 (−13, 20) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Reintervention | 6 mo | 29 (29) | 4 (5) | OR 0.77 (NS) RD 3.4 (−22, 15) | C Medium
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | Reintervention | 12 mo | 29 (29) | 7 (8) | OR 0.84 (NS) RD 3.4 (−26, 19) | C Medium

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 17484536^110^.

Table 34 ABI: Drug-eluting stent versus bare stent

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Drug (Bare) Stent | Baseline Drug (Bare) Stent | Final Drug (Bare) Stent | Net Change (95% CI) | Quality Applicability
RCT
| | Fem-Pop
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | 24 mo | 35 [47 base] (37 [46 base]) | ~0.67 (~0.63) | 0.90 (0.84) | (NS) C | C Medium
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898 D | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | 6 mo | 29 (29) | 0.71 (0.76) | 0.96 (0.90) | 0.11 (0.02, 0.20) E | C Medium

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Comparison of final values.

D Also 17484536^110^.

E Estimated from reported data.

Table 35 Clinical status and reintervention: Stent+Brachy versus Stent

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Outcome | Time | No. Analyzed Stent+Brachy (Stent) | Events | OR (Significance) | Quality Applicability
RCT
| | Fem-Pop
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | Clinical status (Improvement SVS) | 12 mo | 42 (46) | 26 (25) | 1.37 (NS) | B Narrow
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | Clinical status (Improvement SVS) | 24 mo | 42 (46) | 24 (23) | 1.33 (NS) | B Narrow
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | Reintervention | 6 mo | 42 (46) | 14 (10) | 1.78 (NS) [RD 12 (−7, 30)] | B Narrow

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

Table 36 Walking distance and ABI: Stent+Brachy versus Stent

Study Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Outcome | Time | No. Analyzed Stent+Brachy (Stent) | Baseline Stent+Brachy (Stent) | Final Stent+Brachy (Stent) | Net Change (95% CI) | Quality Applicability
RCTs
| | Fem-Pop
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (Fontaine 2–4 100%) | Balloon or self-expanding | 0%/0% (nd) | Walking distance | 12 mo | 17 [37 base] (12 [33 base]) | 147 C (113) | 384 (329) | 21 (−118, 160) D | C Narrow
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (Fontaine 2–4 100%) | Balloon or self-expanding | 0%/0% (nd) | ABI | 6 mo | 30 [46 base] (28 [42 base]) | 0.55 (0.60) | 0.74 (0.89) | −0.10 (−0.20, 0.001) D | C Narrow
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (Fontaine 2–4 100%) | Balloon or self-expanding | 0%/0% (nd) | ABI | 12 mo | 19 [46 base] (24 [42 base]) | 0.55 (0.60) | 0.71 (0.91) | −0.15 (−0.26, −0.04) D | C Narrow

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Only among those without chronic limb ischemia or orthopedic problems; 3.2 km/hr and 12° incline; maximal distance was 700 m.

D Estimated from reported data.

### 3.4.4 Procedure-Related Complications

#### Postoperative complications

(Tables 37 & 38; Figure 14)

##### Studies

Fifteen studies reported on postoperative complications within 30 days of the procedures. All reported major complications (though one only implied that there were no complications104).56,76,79,93,94,98,101,104,105,109,112–116 Six of the studies also explicitly reported minor complications.76,94,101,104,109,112 Several studies reported complications for all evaluated patients but did not clarify which intervention the patients had, and are thus not included here.

Eight of the RCTs reported major complications.56,76,93,94,98,101,104,105 The remaining studies included one prospective comparative study109 and six retrospective comparative studies.79,112–116 All but three of the studies compared stent placement with PTA. Wolfram 2005^104^ compared stent with and without brachytherapy; Siablis 2005^109^ compared bare and drug-eluting stents; Kedora 2007^76^ compared stent to bypass surgery. The reporting times varied from peri- and postoperative to 30 days, including one study that included bleeding only during the hospitalization and one that did not report the timing.

##### Outcome definitions

This report uses the general definition for major complications used by most studies, namely a post-procedure complication, within 30 days of the procedure, that requires additional interventions such as surgery, medical therapy, prolonged hospitalization, or that has a substantive negative impact on patient health or well-being. When necessary, we reclassified complications to meet this definition. Minor complications were those that required at most conservative treatment, not requiring subsequent interventions.

##### Results

Across the studies the rate of major complications after stent placement ranged from 0 percent (5 studies) to 13 percent (3 of 23 patients), with a median of 3 percent (Table 37). In total, 31 of 792 patients (3.9 percent by metaanalysis) receiving stents were reported to have major complications. After PTA, between 0 percent (5 studies) and 24 percent (4/17) of patients had major complications, with a median of 1.5 percent. In total, 43 of 1212 patients (3.5 percent by metaanalysis) receiving PTA were reported to have major complications. One of the 46 patients who had bypass had major complications.

Among the six RCTs that compared stent and PTA, two had no major complications after either procedure and no statistically significant differences in rates of major complications were found between the two procedures (ranging from −17 to +4.2 percent). The summary risk difference of major complications was −0.5 percent (95% CI, −2.7 to 1.8 percent; favoring stents) (Figure 14). Among the six retrospective studies that compared PTA and stent, three had no episodes of major complications and the risk difference of major complications after stent versus PTA ranged from 0 to +11 percent, without statistical significance. The retrospective studies used a variety of stent types. The studies are insufficient to adequately assess differences in complication rates for differences in anatomy, stent or balloon types, patient characteristics, or other factors.

Six studies reported on minor complications after either stent, PTA, or bypass (Table 38). Interpretation of the results of this outcome is complicated by the inconsistent reporting of the outcome and by the subjective nature of what constitutes a minor complication (as opposed to a nonreported event). One study94 reported only that there was no significant difference in the number of minor complications between patients receiving stent or PTA. Minor complications were reported in 0 to 29 percent (6/29) of patients after stent and in 2 to 4 percent of patients after PTA. None of the risk differences was statistically significant. The RCT that compared stent to bypass found no difference in rates of minor complications. The two studies that compared different stent interventions also found no differences in minor complication rates.

Figure 14 Random effects model metaanalysis of risk difference for major complications in stent versus PTA trials

* Grimm implied that no major complications were observed, without clearly stating so.

Appl: applicability (H, high; M, medium; N, narrow); Ball: balloon expandable; CI: confidence interval; d: days; DIST: Dutch Iliac Stent Trial; Qual: quality (A, good; B, fair; C, poor); RD: Risk difference; Self: self-expanding.

Shown is a forest plot (typical meta-analysis plot) that describes the risk difference for major complications in 6 trials (1 for iliac artery, 5 for femoral artery). Overall, the summary meta-analysis is nonsignificant regardless of whether 2 trials that have no events on either arm are added to the analyses or not. There is no evidence for statistical heterogeneity in these trials. [Select text description below for tabulation]

##### Summary

Across 15 studies that compared either stent placement to PTA, stent to bypass, or different stent interventions, no consistent or statistically significant differences were found in either major or minor complication rates. Metaanalysis of stent versus PTA RCTs also found no difference in major complications rates The evidence suggests no difference in rates of major and minor complications among interventions, though the small number of studied patients precludes a definitive conclusion regarding relative risks of complications. The evaluation of minor complications is also inconclusive due to the incomplete reporting and the subjective nature of this outcome across studies. Whether differences in patient, clinician, or intervention characteristics affect complication rates could not be assessed.

Table 37 Major Complications

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events (Details) | | | | RD, % (95% CI) | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | Stent 1 | Stent 2 | PTA | Bypass | RD, % (95% CI) | Quality Applicability
RCT
| | Iliac
Dutch Iliac Stent Trial 1998^56^ 16371580^C^ | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | Post-op | 143 (136) | 6 | | 10 | | 1.9 (−1.7, 5.5) | A Medium
Dutch Iliac Stent Trial 1998^56^ 16371580^C^ | 1993–1996 (58 yr) | Iliac (7%) | Balloon | 43%/nd (ITT) | Post-op | 143 (136) | D | | | | 1.9 (−1.7, 5.5) | A Medium
| | Fem-Pop
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | 121 (123) | 2^E^ | | 3^F^ | | −0.8 (−4.3, 2.8) | A Medium
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 30 d | 115 (112) | 10^G^ | | 5^G^ | | 4.2 (−2.2, 11) | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | 30 d | 77 (77) | 1^H^ | | 2^H^ | | −1.3 (−5.7, 3.1) | B High
Schillinger 2007^102^ 17502568^J^ | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 30 d | 46 (42) | 0 | | 0 | | 0 | A High
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | <1 mo | 46 (42^K^) | 1^L^ | 1^L^ | | | | B Narrow
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fem-Pop (27%) | Self-expanding, covered | 0%/0% (nd) | Post-op | 40 (46) | 1^M^ | | | 1^N^ | 0.3 (−6.1, 6.7) | B Medium
Grimm 2001^98^ 9203369 | nd (70 yr) | SFA (79%) | Balloon | 0%/0% (nd) | Post-op | 30 (23) | 0 | | 0 | | 0 | C Medium
Zdanowski 1999^105^ 10811511 | nd (73 yr) | SFA (85%) | Balloon | 0%/0% (no) | 30 d | 15 (17) | 1^P^ | | 4^Q^ | | −17 (−41, 7) | C Medium
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898^R^ | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | 30 d | 29 (29) | 1^S^ | 0^T^ | | | 3.4 (−3.2, 10) | C Medium
Retrospective
| | Mixed
Burns 2000^112^ 11232893 | 1997–1998 (69 yr) | Aorto-iliac 47% Fem-Pop 43% (nd, included gangrene) | nd | NA | Hospitalization | 34 (206) | 3^U^ | | 2^V^ | | 7.8 (−1.8, 17) | C High
| | Aorto-iliac
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | Peri-op | 34 (117) | 0 | | 0 | | 0 | C High
Laxdal 2007^114^ 17258418 | 1990–2003 (55 yr) | Infrarenal aorta (0%) | Balloon or self-expanding | NA | 30 d | 17 (13) | 0 | | 0 | | 0 | C Narrow
| | Fem-Pop
Schillinger 2003^116^ 12877612 | 1998–2000 (71 yr) | SFA (29%) | Balloon | NA | Peri-op | 58 (357) | 3 | | 18 | | 0.1 (−6.0, 6.3) | C High
Schillinger 2003^116^ 12877612 | 1998–2000 (71 yr) | SFA (29%) | Balloon | NA | Peri-op | 58 (357) | W | | | | 0.1 (−6.0, 6.3) | C High
Pozzi Mucelli 2003^115^ 12835627 | 1995–2001 (67 yr) | Fem-Pop (54%) | Balloon or self-expanding | NA | 30 d | 23 (86) | 3^X^ | | 2^X^ | | 11 (−3, 25) | C High
Cho 2003^113^ 12668846 | 1999–2002 (71 yr) | SFA (0%) | Self-expanding | NA | nd | 14 (26) | 0 | | 0 | | 0 | C Narrow

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 8994707^57^, 9643685^95^, 10377079^55^, 15286319^96^.

D Hematoma, arterial wall perforation, acute occlusion, embolism, vasovagal collapse.

E False aneurysm.

F False aneurysm, arteriovenous fistula.

G Thrombosis, embolus, arterial rupture, introducer site problems.

H Unclear what the complication was.

J Also 16672699^101^.

K Plus brachytherapy.

L Distal embolization requiring embolectomy (classified as minor complication by authors).

M Limb pain.

N Lymphocele.

P Bleed, embolus.

Q Myocardial infarction, bleed.

R Also 17484536^110^.

S Sirolimus; myocardial infarction.

T Bare.

U Hematoma, false aneurysm, immediate occlusion, embolus.

V Arterial rupture, embolus.

W Vessel ruptures, emboli, AVF, pseudoaneurysm

X Hematoma, embolism.

Table 38 Minor Complications

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events (Details) | | | | RD, % (95% CI) | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | Stent 1 | Stent 2 | PTA | Bypass | RD, % (95% CI) | Quality Applicability
RCT
| | Fem-Pop
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | 121 (123) | 6^C^ | | 1^D^ | | −4.1 (−0, 8.3) | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | 30 d | 77 (77) | NS^E^ | | NS^E^ | | nd | B High
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | <1 mo | 46 (42^F^) | 4^G^ | 3^F,H^ | | | 0.6 (−11,10) | B Narrow
Schillinger 2007^102^ 17502568^J^ | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 30 d | 46 (42) | 0 | | 1^K^ | | −2.4 (−7.0, 2.2) | A High
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fem-Pop (27%) | Self-expanding, covered | 0%/0% (nd) | Post-op | 40 (46) | 3^L^ | | | 2^M^ | 3.2 (−6.9, 13) | B Medium
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898^N^ | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | 30 d | 29 (29) | 6^P,Q^ | 5^Q,R^ | | | 3.4 (−17, 24) | C Medium
Retrospective
| | Mixed
Burns 2000^112^ 11232893 | 1997–1998 (69 yr) | Aorto-iliac 47% Fem-Pop 43% (nd, included gangrene) | nd | NA | Hospitalization | 34 (206) | 1^S^ | | 8^T^ | | −0.9 (−7.2, 5.3) | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Hematoma, dissection, closure device failure.

D Dissection.

E No significant difference between interventions. Number of events not reported.

F Plus brachytherapy.

G Pseudoaneurysm, bleed.

H Pseudoaneurysm.

J Also 16672699^101^.

K Peripheral embolization.

L Dissection, edema, hematoma.

M Seroma, superficial wound dehiscence.

N Also 17484536^110^.

P Sirolimus.

Q Hematoma, pseudo-aneurysm.

R Bare.

S Hematoma.

T Hematoma, embolus.

#### Postoperative bleeding

(Tables 39–41; Figure 15)

##### Studies

Fourteen studies reported on postoperative bleeding within 30 days of the procedure. Seven of these studies explicitly reported major bleeding events93,94,100,105,112,114,115 while seven reported other postoperative complications but did not describe major bleeding, implying that no patients experienced this complication.76,79,98,103,104,109,117 Six of these studies also reported minor bleeding events.76,79,104,109,112,117

Eight of the RCTs reported on bleeding.76,93,94,98,100,103–105 The remaining studies included one prospective comparative study109 and five retrospective comparative studies.79,112,114,115,117 All but three of the studies compared stent placement with PTA. Wolfram 2005^104^ compared stent with and without brachytherapy; Siablis 2005^109^ compared bare and drug-eluting stents; Kedora 2007^76^ compared stent to bypass surgery. The reporting times varied from peri- and postoperative to 30 days, including one study that included bleeding only during the hospitalization and one that did not report the timing.

##### Outcome definitions

Slightly different definitions were used for major bleeding, though the general concept was the same for all studies. Bleeding was defined as major if the patients required blood transfusions, surgery or other invasive intervention to stop the bleeding, or that prolonged hospital stay or affected the patient’s general health. Across studies, bleeding was defined as minor if only local hematomas occurred that required only conservative treatment (such as local pressure).

##### Results

Across the studies the rate of major bleeding after stent placement (Tables 39 & 40) ranged from 0 percent (10 studies) to 7 percent (1 of 15 patients). In total, 7 of 554 patients (1.3 percent by metaanalysis) receiving stents were reported to have major bleeding. After PTA, between 0 percent (5 studies) and 18 percent (3/17) of patients had major bleeding. In total, 10 of 597 patients (1.7 percent by metaanalysis) receiving PTA were reported to have major bleeding. None of the 40 patients who had bypass had major bleeding. Among the six RCTs that compared stent and PTA, three had no episodes of major bleeding after either procedure and no statistically significant differences in rates of major bleeding were found between the two procedures. The summary risk difference of major bleeding was 0 percent (95% CI −2.3 to 2.5 percent). Excluding trials with no events in both arms resulted in similar estimates (Figure 15). One study had 3 percent more bleeding (absolute difference) after stent placement93 and two had 3 and 11 percent more bleeding after PTA94,105; these three studies used balloon-expanded stents so all patients effectively had balloon angioplasty. Among the four retrospective studies that compared PTA and stent, two had no episodes of major bleeding and the risk difference of major bleeding after stent versus PTA ranged from 0 to +2.5 percent, without statistical significance. The retrospective studies used a variety of stent types. The studies are insufficient to adequately assess differences in bleeding rates for differences in anatomy, stent or balloon types, patient characteristics, or other factors.

Figure 15 Random effects model metaanalysis of risk differences for major bleeding in trials comparing stents versus PTA

Appl: Applicability (H, high; M, medium; N, narrow); :Ball: balloon expandable; CI: confidence interval; d, days; postop: postoperative period (not clearly defined); PTA, percutaneous transluminal angioplasty; Qual: quality (A, good; B, fair; C, poor); RD: Risk difference; Self: self-expanding.

Shown is a forest plot (typical meta-analysis plot) that describes the risk difference for major bleeding in 6 trials on the treatment of femoral artery lesions. Overall, the summary meta-analysis is nonsignificant regardless of whether 3 trials that have no events on either arm are added to the analyses or not. There is no evidence for statistical heterogeneity in these trials [Select text description below for tabulation]

Only three retrospective studies reported on minor bleeding after either stent (a variety of types) or PTA (Table 41). Minor bleeding was reported in 0 to 8 percent (1/12) of patients after stent and in 1 to 31 percent (4/13) of patients after PTA. None of the risk differences was statistically significant. The RCT that compared stent to bypass found no difference in rates of minor bleeding. The two studies that compared different stent interventions also found no differences in minor bleeding rates.

##### Summary

Across 14 studies that compared either stent placement to PTA, stent to bypass, or different stent interventions, no consistent or statistically significant differences were found in either major or minor bleeding rates. However, only about 1 percent of patients experienced major bleeding and the studies were relatively small. Metaanalysis of stent versus PTA RCTs also found no difference in major complications rates. The evidence suggests no difference in rates of major and minor bleeding between interventions, though the small number of studied patients precludes a definitive conclusion regarding relative risks of bleeding. It could not be assessed whether differences in patient, clinician, or intervention characteristics affect complication rates.

Table 39 Major Bleeding

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events | | | | RD, % (95% CI) | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover^B^, % (ITT?) | Time | No. Analyzed Stent (Control) | Stent 1 | Stent 2 | PTA | Bypass | RD, % (95% CI) | Quality Applicability
RCT
| | Fem-Pop
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 30 d | 115 (112) | 4 | | 1 | | 2.6 (−1.2, 6.4) | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | 30 d | 77 (77) | 0 | | 2 | | −2.6 (−6.2, 1.0) | B High
Zdanowski 1999^105^ 10811511 | nd (73 yr) | SFA (84%) | Balloon | 0%/0% (no) | 30 d | 15 (17) | 1 | | 3 | | −11 (−33, 11) | C Medium
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Covered, self-expanding | 6%/0% (ITT) | Post-op | 15 (13) | 0 | | 0 | | 0 | C Narrow
Retrospective
| | Mixed
Burns 2000^112^ 111232893 | 1997–1998 (68 yr) | Aorto-iliac 47% Fem-Pop 43% (nd, included gangrene) | nd | NA | Hospitalization | 34 (206) | 1 | | 1 | | 2.5 (−3.3, 8.2) | C High
| | Aorto-iliac
Laxdal 2007^114^ 17258418 | 1990–2003 (55 yr) | Infrarenal aorta (0%) | Balloon or self-expanding | NA | 30 d | 17 (13) | 0 | | 0 | | 0 | C Narrow
| | Fem-Pop
Pozzi Mucelli 2003^115^ 12835627 | 1995–2001 (67 yr) | Fem-Pop (54%) | Balloon or self-expanding | NA | 30 d | 23 (86) | 1 | | 3 | | 0.9 (−8.3, 10) | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

Table 40 Major Bleeding – No Events

The following studies implied that there was no major bleeding in either arm. They reported adverse events but did not explicitly document major bleeding.

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed | | | | Quality Applic.
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | Stent 1 | Stent 2 | PTA | Bypass | Quality Applic.
RCT
| | Fem-Pop
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | <1 mo | 46 | 42 C | | | B Narrow
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fem-Pop (27%) | Self-expanding, covered | 0%/0% (nd) | Post-op | 46 | | | 40 | B Medium
Grimm 2001^96^ 9203369 | nd (70 yr) | SFA (79%) | Balloon | 0%/0% (nd) | Post-op | 30 | | 23 | | C Medium
Vroegindeweij 1997^103^ 9354709 | 1993–1995 (65 yr) | Fem-Pop (18%) | Balloon | 0%/8% (ITT) | 1 mo | 24 | | 27 | | C Medium
Prospective
| | Infrapopliteal
Siablis, 2005^109^ 16363898^D^ | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | nd | 29 E | 29 F | | | C Medium
Retrospective
| | Aorto-iliac
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | Peri-op | 34 | | 117 | | C High
Westcott 1998^117^ 9540904 | nd (56 yr) | Infrarenal aorta (12%) | Balloon | NA | Immediate post-op | 12 | | 13 | | C Narrow

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Plus brachytherapy.

D Also 17484536^110^

E Sirolimus.

F Bare.

Table 41 Minor Bleeding

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events | | | | RD, % (95% CI) | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | Stent 1 | Stent 2 | PTA | Bypass | RD, % (95% CI) | Quality Applicability
RCT
| | Fem-Pop
Kranken berg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11 %/nd (both) | 12 mo | 121 (123) | 3 | | 0 | | 2.5 (−0.3, 5.2) | A Medium
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | <1 mo | 46 (42^C^) | 1 | 0^C^ | | | 2.2 (−2.0, 6.4) | B Narrow
Kedora 2007^76^ 1716520 | 2004–2005 (69 yr) | Fem-Pop (27%) | Self-expanding, covered | 0%/0% (nd) | Post-op | 40 (46) | 1 | | | 0 | 2.5 (−2.4, 7.3) | B Medium
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898^D^ | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | 30 d | 29 (29) | 45^E^ | F | | | 3.4 (−15, 22) | C Medium
Retrospective
| | Mixed
Burns 2000^112^ 11232893 | 1997–1998 (69 yr) | Aorto-iliac 47% Fem-Pop 43% (nd, included gangrene) | nd | NA | Hospitalization | 34 (206) | 1 | | 8 | | −0.9 (−7.2, 5.3) | C High
| | Aorto-iliac
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | Peri-op | 34 (117) | 0 | | 1 | | −0.9 (−2.5, 0.8) | C High
Westcott 1998^117^ 9540904 | nd (56 yr) | Infrarenal aorta (12%) | Balloon | NA | Immediate post-op | 12 (13) | 1 | | 4 | | −22 (−52, 7) | C Narrow

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Plus brachytherapy.

D Also 17484536^110^.

E Sirolimus.

F Bare.

#### Embolic events

(Table 42; Figure 16)

##### Studies

Seven studies reported on embolic events within 30 days of the procedures.93,94,100,101,103,104,115 Six of the RCTs reported on emboli and one retrospective comparative study.115 All but one compared stent placement with PTA. Wolfram 2005^104^ compared stent with and without brachytherapy. None evaluated bypass surgery. The reporting times varied from postoperative to 30 days.

##### Outcome definitions

All but one study reported on emboli that required intervention, presumably due to signs or symptoms of compromised blood flow. Removal of the emboli was achieved with either thrombolysis, aspiration, or embolectomy. Only Becquemin 2003^93^ reported on emboli without either describing how the emboli were diagnosed or treated. Saxon 2003^100^ reported on both emboli that were asymptomatic and diagnosed by angiography alone and one embolus that required treatment. Only treated emboli are included here.

##### Results

Across the studies the rate of emboli after stent placement ranged from 0 percent (1 study) to 7 percent (1 of 15 patients), with a median of 4 percent. In total, 12 of 393 patients (3.4 percent by metaanalysis) receiving stents had emboli requiring treatment. After PTA, between 0 percent (2 studies) and 5 percent (4/77) of patients had emboli, with a median of 1.5 percent. In total, 8 of 368 patients (2.6 percent by metaanalysis) receiving PTA had emboli.

Among the five RCTs that compared stent and PTA, there were no statistically significant differences in emboli rates between the two procedures (ranging from −1.9 to +6.7 percent). The summary risk difference of major complications was 0.7 percent (95% CI, −2.1 to 3.5 percent; favoring PTA); the RCTs had statistically homogeneous results (Figure 16). The retrospective study similarly found no significant difference in emboli rates. The studies are insufficient to adequately assess differences in emboli rates for differences in anatomy, stent or balloon types, patient characteristics, or other factors.

##### Summary

Across seven studies that compared either stent placement to PTA, or stent to bypass no consistent or statistically significant differences were found in rates of postoperative emboli requiring treatment. Metaanalysis of stent versus PTA RCTs also found no difference in emboli rates. The evidence suggests no difference in emboli rates among interventions, though the small number of studied patients precludes a definitive conclusion regarding relative risks of complications. It could not be assessed whether differences in patient, clinician, or intervention characteristics affect complication rates.

Figure 16 Random effects model metaanalysis of risk difference foremboli within 30 days in stent versus PTA trials

Appl: Applicability (H, high; M, medium; N, narrow); Ball: balloon expandable; CI: confidence interval; d, days; post-op, postoperative period (not clearly defined); PTA, percutaneous transluminal angioplasty; Qual: quality (A, good; B, fair; C, poor); RD: Risk difference; Sekf: self-expanding.

Shown is a forest plot (typical meta-analysis plot) that describes the risk difference for emboli in 5 trials on the treatment of femoral artery lesions. Overall, the summary meta-analysis is nonsignificant. There is no evidence for statistical heterogeneity in these trials. Go to Text Description below for tabulation of the numbers]

#### 30-day mortality

(Table 43; Figure 17)

##### Studies

Eight studies reported all-cause mortality within 30 days of followup. These included three RCTs,93,94,105 one prospective comparative study109, and four retrospective comparative studies.79,111,114,115 Six of the studies compared stent to PTA; the prospective study compared bare stents to drug-eluting stents, and one retrospective study compared stent to bypass. Two retrospective studies reported “perioperative” deaths; the rest clearly reported 30-day mortality.

##### Results

Six of the eight studies had no deaths within 30 days of the procedures. Cejna 2001^94^ had two deaths after PTA. One patient died of a myocardial infarction on day 17 and one patient died of sepsis 27 days after PTA. Ballard 1998^111^ had one death after surgical bypass in a patient who had a myocardial infarction and cardiac failure. Overall across studies, none of 404 patients who had stents died within 30 days, 2 of 422 patients assigned to PTA died, and 1 of 54 patients who had bypass died perioperatively. None of studies found a significant difference in 30-day mortality between stent and an alternate intervention. The summary risk difference across the three RCTs comparing stents and PTA was −0.3 percent (95% CI −1.9, 1.2 percent).

Table 42 Embolic Events

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events | | | | RD, % (95% CI) | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | Stent 1 | Stent 2 | PTA | Bypass | RD, % (95% CI) | Quality Applicability
RCT
| | Fem-Pop
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | 121 (123) | 0 | | 0 | | 0 | A Medium
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 30 d | 115 (112) | 5 | | 2 | | 2.6 (−1.9, 7.0) | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | 30 d | 77 (77) | 3 | | 4 | | −1.3 (−7.9, 5.3) | B High
Schillinger 2007^102^ 17502568 C | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32%/nd (ITT) | 30 d | 51 (53) | 0 | | 1 | | 1.9 (−5.6, 1.8) | A High
Wolfram 2005^104^ 15987985 | 1999–2002 (68 yr) | Fem-Pop (13%) | Balloon or self-expanding | 0%/0% (nd) | <1 mo | 46 (42 D) | 1 | 0 D | | | 2.2 (−2.0, 6.4) | B Narrow
Vroegindeweij 1997^103^ 9354709 | 1993–1995 (65 yr) | Fem-Pop (18%) | Balloon | 0%/8% (ITT) | 1 mo | 24 (27) | 1 | | 0 | | 4.2 (−3.8, 12) | B Medium
Saxon 2003^100^ 12631634 | 1998–1999 (70 yr) | SFA (SVS 2.3, mean) | Covered, self-expanding | 6%/0% (ITT) | Post-op | 15 (13) | 1 E | | 0 | | 6.7 (−6.0, 19) | C Narrow
Retrospective
| | Fem-Pop
Pozzi Mucelli 2003^115^ 12835627 | 1995–2001 (67 yr) | Fem-Pop (54%) | Balloon or self-expanding | NA | 30 d | 23 (86) | 1 | | 1 | | 3.2 (−5.5, 12) | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 16672699^101^.

D Plus brachytherapy.

E Also 2 asymptomatic emboli discovered by angiography alone. No treatment required.

##### Summary

The perioperative mortality after PTA or stent placement is very low. The very small number of perioperative deaths among the studies (none for PTA) precludes an accurate estimate of perioperative mortality. From these studies, though the approximate estimates of perioperative deaths are less than 1 in 400 after stent, about 1 in 200 after PTA, and about 1 in 50 after bypass. However, the evidence does not support any meaningful differences in perioperative mortality.

Figure 17 Random effects model of risk difference of 30 day mortality in stent versus PTA trials

Appl: applicability (H, high; M, medium); Ball: balloon expandable; CI: confidence interval; d: days; RD: Risk difference; PTA, percutaneous transluminal angioplasty; Qual: Quality (A, good; B, fair; C, poor).

Shown is a forest plot (typical meta-analysis plot) that describes the risk difference for 30 day mortality in 3 trials on the treatment of femoral artery lesions. Overall, the summary meta-analysis is nonsignificant regardless of whether the 2 trials that have no events on either arm are added to the analyses or not. There is no evidence for statistical heterogeneity in these trials. Go to Text Description below for the tabulation of the numbers]

#### Stent Fractures

(Table 44)

##### Studies

Four studies reported rates of stent fractures. These included three RCTs40,97,101 and one prospective comparative study.109 The three RCTs all evaluated self-expanding stents in the superficial femoral artery; the prospective study evaluated balloon expanded stents in the infrapopliteal segments. All studies primarily evaluated stent fractures based on ultrasonography, though two of the trials also reported clinical consequences.

##### Results

The studies found widely varying rates of stent fractures. In the small prospective study of balloon expanded stents in the infrapopliteal arteries, none of 58 stents were found to be fractured at 30 days. Schillinger 2006 also found a low rate of stent fracture (2 percent) in 49 patients receiving self-expanding stents in the superficial femoral artery at 1 year. The article provided no data regarding any clinical consequences of the stent fracture in the on one patient.

Table 43 30-day mortality

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | No. Events (Details) | | | | RD, % (95% CI) | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, % A) | Stent Type | Xover B, % (ITT?) | Time | No. Analyzed Stent (Control) | Stent 1 | Stent 2 | PTA | Bypass | RD, % (95% CI) | Quality Applicability
RCT
| | Fem-Pop
Becquemin 2003^93^ 12618680 | 1995–1997 (67 yr) | SFA (21%) | Balloon | 13%/1% (ITT) | 30 d | 115 (112) | 0 | | 0 | | 0 | A Medium
Cejna 2001^94^ 11200349 | 1994–1997 (67 yr) | Fem-Pop (86%) | Balloon | 13%/1% (ITT) | 30 d | 77 (77) | 0 | | 2 | | −2.6 (−6.2, 1.0) | B High
Zdanowski 1999^105^ 10811511 | nd (73 yr) | SFA (85%) | Balloon | 0%/0% (no) | 30 d | 15 (17) | 0 | | 0 | | 0 | C Medium
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898 C | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | NA | 30 d | 29 (29) | 0 0 D | E | | | 0 | C Medium
Retrospective
| | Aorto-iliac
Ballard 1998^111^ 9685135 | 1992–1996 (65 yr) | Aorto-iliac (85%) | Balloon | NA | Peri-op | 65 (54) | 0 | | | 1 | −1.9 (−5.4, 1.7) | C High
Kudo 2005^79^ 16171589 | 1993–2004 (67 yr) | Iliac (50%) | Balloon or self-expanding | 29%/NA (NA) | Peri-op | 34 (117) | 0 | | 0 | | 0 | C High
Laxdal 2007^114^ 17258418 | 1990–2003 (55 yr) | Infrarenal aorta (0%) | Balloon or self-expanding | NA | 30 d | 17 (13) | 0 | | 0 | | 0 | C Narrow
| | Fem-Pop
Pozzi Mucelli 2003^115^ 12835627 | 1995–2001 (67 yr) | Fem-Pop (54%) | Balloon or self-expanding | NA | 30 d | 23 (86) | 0 | | 0 | | 0 | C High

A Ischemic rest pain or greater severity.

B Percent assigned to PTA who received stent / Percent assigned to stent who received only PTA.

C Also 17484536^110^.

D Sirolimus.

E Bare.

Krankenberg 2007 found a higher rate of stent fractures (12 percent) in 83 patients with self-expanding stents also in the superficial femoral artery. The article did not report what clinical consequences ensued from the stent fractures, except to note that there was no difference in restenosis rates between those patients with and without stent fractures. The remaining study, Duda 2006, had the highest rate of stent fractures (26 percent, overall) in 65 patients treated with self-expanding stents in the superficial femoral artery at 18 months. This study included patients who were treated earlier (including prior to 2003) than the other studies. All the patients were asymptomatic, though one patient had a prophylactic graft stent placed due to a 12 mm ulcer that was visible at the strut fracture site.

##### Summary

Overall, only a few studies evaluated stent fracture rates in a total of 255 patients. The rates of stent fractures ranged from 0 percent in the prospective study to 26 percent in a trial that included patients treated prior to those included in other studies. Reporting on clinical consequences were incomplete, but no patients were reported to have clinical symptoms due to the stent fractures while one patient had a prophylactic reintervention due to an ulcer forming at the site of the stent fracture.

#### Patient or Lesion Characteristics as Predictors of Clinical Outcomes

(Table 45)

Only two studies reported subgroup analyses that evaluate potential predictors of clinical outcomes, including one RCT96 and one retrospective study79 comparing stent to PTA. The majority of trials that reported analyses of predictors of outcomes evaluated various definitions of patency as the outcome. A review of direct and indirect comparisons of patients by TASC category is in Section 3.3.

The Dutch Iliac Stent Trial compared primary balloon-expandable stent placement in the iliac artery with selective stent placement (43 percent of patients had secondary stent placement based on hemodynamically significant gradients after angioplasty). In a Cox regression, multivariable analysis, they evaluated the risk of reintervention. Since they found no difference in outcome based on intervention group, this variable (primary versus selective stent) was not included in the model.

Kudo 2005 was a retrospective analysis of balloon-expandable stent versus PTA in the iliac artery. In a Cox regression, multivariable analysis, they evaluated the risk of clinical failure, defined as failure to improve by at least one clinical category in the SVS/ISCVS system. It is implied in the article that the variable stent versus PTA was not included in the model.

Table 45 presents the evaluated risk factors in the 2 studies. The only agreement between the two studies of risk factors that predict poor outcome was clinical severity of PAD. The Dutch Iliac Stent Trial found as trend that those with Fontaine III or IV disease were twice as likely to require a reintervention; Kudo 2005 found a similar trend for patients with rest pain (HR=2.45, P=.10) and a strong association of gangrene with clinical failure (HR=6.3, P=.0002).

The two studies came to opposite conclusions as to whether women or men were at higher risk of outcome failure; the Dutch trial found that elevated serum creatinine was not a risk factor, but Kudo 2005 found that patients on hemodialysis faired significantly worse. The Dutch trial also found as a trend that iliac stenosis over 2 cm in length predicted poor outcomes (not evaluated by Kudo 2005) and Kudo found that ipsilateral superficial femoral artery stenosis of at least 50 percent (compared to vessel occlusion) predicted clinical failure (not evaluated by the Dutch trial).

Table 44 Stent fractures

Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | No. Events | | | | Clinical Consequences | Quality Applicability
Study, Year UI | Intervention Years (Mean Age) | Artery (CLI, %^A^) | Stent Type | Xover^B^, % (ITT?) | Time | Balloon, bare | Balloon, drug eluting | Self- expanding, bare | Self- expanding, drug eluting | Clinical Consequences | Quality Applicability
RCT
| | Fem-Pop
Krankenberg 2007^40^ 17592075 | 2004–2005 (66 yr) | SFA (3%) | Self-expanding | 11%/nd (both) | 12 mo | | | 10/83 (12%) | | No difference in restenosis rate between those with and without stent fracture | A Medium
Duda 2006^97^ 17154704 | ≥2001 (66 yr) | SFA (SVS 3+4 57%) | Self-expanding (drug vs. bare) | 0%/0% (nd) | 18 mo | | | 8/40 (20%) | 9/25 (36%) | All asymptomatic. 1 patient had covered graft stent placed prophylactically due to 12 mm ulcer at strut fracture site | B Medium
Schillinger 2006^101,102^ 16672699 | 2003–2004 (66 yr) | SFA (13%) | Self-expanding | 32% (ITT) | 12 mo | | | 1/49 (2%) | | nd | A High
Prospective
| | Infrapopliteal
Siablis 2005^109^ 16363898^C^ | 2003–2004 (69 yr) | Infrapopliteal (100%) | Balloon (drug vs. bare) | N/A | 30 d | 0/29 | 0/29 | | | NA | C Medium

The two studies agreed that the classic cardiovascular risk factors (tobacco use, hypertension, diabetes, and hypertension) did not predict worse clinical outcomes. Other measures of lesion characteristics or PAD severity (including ABI and walking distance) failed to independently predict poor clinical outcomes.

It is important to note that no study evaluated whether any intervention may be superior to another for any subgroup of patients (for example, whether those with longer occlusions should receive a stent instead of PTA).

Table 45 Predictors of clinical outcomes by multivariable analysis (Cox regression)

Predictor | | Dutch Iliac Stent Trial HR (95% CI) | Kudo 2005 HR [P value]
| Artery (Stent): | Iliac (Balloon) | Iliac (Balloon)
| Outcome: | Reintervention | Clinical Failure^*^
| Study Design: | RCT | Retrospective
Demographic
Sex | | Female 2.1 (1.2, 3.7) | Male 2.51 [.053]
Age ≥65 yr | | | 2.78 [.025]
Cardiovascular Risk Factors
Tobacco use | | NS | NS
Hypertension | | NS | NS
Diabetes | | NS | NS
Hyperlipidemia | | NS | NS
Kidney disease | | NS (elevated Cr) | 3.16 [.03] (hemodialysis)
CAD | | | NS
PAD Severity
Fontaine III/IV | | 2.0 (0.9, 4.7)
Rest pain | | | 2.45 [.10]
Ulcer or gangrene | | | 6.28 [.0002]
ABI (rest or exercise) | | NS
Walking distance | | NS
PAD Characterization
Iliac stenosis >2 cm | | 1.6 (0.9, 2.7)
Common vs. external iliac artery | | NS | NS
Lesion morphology | | NS
Patency of runoff vessels | | NS
Former recanalization | | NS
Ipsilateral SFA patent (vs. occluded) | | | NS
Ipsilateral SFA stenosis >50% (vs. occluded) | | | 3.31 [.02]

* Failure to improve by at least 1 clinical category per SVS/ISCVS.

ABI, ankle brachial index; CI, confidence interval; Cr, serum creatinine; HR, hazard ratio; NS, not statistically significant (not included in multivariable model); RCT, randomized controlled trial; SFA, superficial femoral artery.