# Methods

This report on the use of peripheral stents in the treatment of peripheral artery disease is based on a systematic review of the literature.

For the background information on peripheral artery stents, we performed a horizon scan based on published abstracts on invasive vascular procedures for the treatment of peripheral artery disease (PAD), primarily surgical bypass grafting, angioplasty, angioplasty with stent placement, and atherectomy. We categorized the relevant studies based on intervention; preoperative characteristics of PAD defined by clinical, anatomic, and hemodynamic features (based primarily on TASC II classification schemes); primary outcomes; study design; and sample size.

We also performed a systematic review of the relative safety and effect of peripheral artery stenting with other invasive vascular procedures for occlusive PAD of infrarenal vessels. We included comparisons of different stents and of different procedures with stents. Among comparative studies (stent versus other intervention; stent versus stent), we evaluated the following questions and features:

- Methodological quality of studies
- Applicability of studies to patients aged ≥65 years with occlusive PAD
- Demographic and other preoperative (baseline) features of studied patients
- Clinical, anatomic, and hemodynamic features of PAD lesions (based primarily on TASC II classification schemes)
- Types of the stents used, emphasizing balloon-expandable and self-expanding (e.g., nitinol), bare and drug-eluting or other treated or coated stents
- Concurrent and postoperative treatments, including but not limited to brachytherapy and antiplatelet therapy
- Length of followup
- Persistence of effects over time
- Clinical outcomes (patient survival, limb salvage, pain, quality of life)
- Adverse events (complications attributable to the intervention, as opposed to the underlying disease process)

The approach, methodology, and criteria used were agreed upon by consensus of the Evidence-based Practice Center (EPC) clinician-methodologists, an expert in cardiovascular surgery based at Tufts Medical Center, Centers for Medicare & Medicaid Services (CMS) staff, and staff at the Agency for Healthcare Research and Quality (AHRQ) with methodological expertise.

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the key questions. The final search was conducted on July 19 2007. We searched MEDLINE (from 1950 to present) and the Cochrane Clinical Trial Registry to identify articles relevant to each key question. In electronic searches, we used various terms for PAD and specific interventions for PAD, limited to humans, and relevant research designs (see Appendix A for complete search strategy). The same literature data set was used for the horizon scan and the systematic review. We did not systematically search for unpublished data.

## Study Selection

We assessed titles and abstracts of citations identified from literature searches for inclusion, using the criteria described below. As described below, the horizon scan was based only on the titles and abstracts. For studies that potentially met criteria for the systematic reviews full text articles were retrieved and a second review for inclusion was performed, reapplying the inclusion criteria. A low threshold was used to retrieve articles for full rescreening.

### Eligibility criteria for horizon scan

Population: Adults and children with infrarenal PAD (of the lower extremities); primary or recurrent (previously treated) disease. We limited the horizon scan to chronic PAD, as opposed to acute occlusion, where this determination was possible from the abstract data.

Intervention: Any invasive vascular procedure for the treatment of PAD. We excluded studies that used only medical or other noninvasive therapies (including brachytherapy). No comparator was necessary.

Outcomes: Studies were not excluded based on outcomes reported in the abstract.

Study design: At least 10 subjects receiving each intervention evaluated. Where sample size was not reported in the title or abstract, we retained the abstract. We also included systematic reviews. Narrative reviews were excluded. The abstract had to explicitly state or strongly suggest that it is a systematic review. There was no language restriction.

### Eligibility criteria for TASC II report citations

The TASC II report was reviewed for recommendations regarding choice of intervention. All publications referenced in the text regarding the rationale for the recommendations were retrieved and reviewed. Any primary study was included, only excluding narrative reviews and opinion pieces.

### Eligibility criteria for systematic review of TASC classification

Population: Adults with infrarenal PAD (of the lower extremities); primary or recurrent (previously treated) disease; excluding acute occlusion.

Intervention: Any invasive vascular procedure for the treatment of PAD. We excluded studies that used only medical or other noninvasive therapies (including brachytherapy). No comparator was necessary.

Outcomes: Long-term (≥6 months) clinical outcomes: mortality, amputation, reintervention of the treated vessel or lesion; clinical symptoms; quality of life. At least one of the clinical outcomes had to be mentioned in the title or abstract.

Study design: We included all comparative and noncomparative studies published since 2001, whether prospective or retrospective. Studies had to explicitly report the TASC classification of the patients; we did not attempt to infer the TASC classification from descriptions of the anatomy. Studies had to provide clinical outcome data for at least one group of patients at least 80 percent of whom were had either TASC A, B, A or B, C, D, or C or D disease. For analysis, each TASC group with reported clinical outcomes had to have at least 10 patients. Studies had to be peer reviewed and published in English. Studies were excluded if they did not provide separate data for different procedures (i.e., for bypass, for angioplasty, or for stent).

### Eligibility criteria for systematic review of stent studies

Population: Adult humans with stenotic or occlusive infrarenal PAD. We excluded studies that included more than 20 percent of patients with previous failed procedures, studies with more than 20 percent of subjects had stenosis of a graft, and studies that evaluated patients with concomitant aortic or renal artery stenosis or aneurysms requiring treatment.

Intervention: At least one study arm used stent placement across PAD lesions.

Comparators: At least one study arm using an alternative invasive vascular intervention. These included angioplasty without stent, bypass surgery, atherectomy, or alternative stent interventions (either different stents or an added cointervention). Study arms that used primary angioplasty with secondary stent placement for immediate inadequate treatment were considered to be PTA interventions.

Outcomes: We limited our review to clinical and hemodynamic outcomes. These included mortality (survival), limb salvage (amputation), reintervention (a subsequent procedure), symptoms, change in clinical classification, ulcer healing, quality of life, ankle-brachial index (ABI) or equivalent, and standardized walking time tests or equivalent. In addition we included periprocedure complications attributable to the intervention and stent fractures. We relied on the studies to provide possible complications, but specifically extracted 30-day mortality, arterial bleeding, and emboli. The EPC, together with its domain expert and representatives from AHRQ and CMS agreed that patency rates, measures of residual stenosis, or other surrogate outcomes were not sufficiently clinically important and thus that they would not be reviewed. In general, only clinically relevant outcomes were of interest. Though ankle-brachial index is an outcome that does not directly measure patient events or well-being, we included this as a hemodynamic outcome of interest. We also included stent fractures (whether symptomatic or not) as a complication of interest.

Design: We included all comparative (stent versus comparator) designs, including RCTs, prospective comparative nonrandomized studies, and retrospective comparative analyses. Studies had to be peer reviewed. Studies had to analyze at least 10 subjects per intervention and follow patients for at least 1 month. English language only.

## Data Extraction

### Horizon scan

For the horizon scan, we extracted the following variables: year of publication, study design (single arm, case control, comparative nonrandomized study, RCT, systematic review), number of arms, total number of subjects, start and end year of procedures, average age of participants, followup duration (average or maximum), clinical classification (per SVS), anatomic site of PAD (aorto-iliac, femoral popliteal, tibial, or combination), TASC classification (if explicitly reported), reporting of occlusion rate, types of intervention (PTA, stent, bypass, atherectomy, medical without invasive intervention, and other), use of brachytherapy, types of outcomes reported (symptomatic relief, amputation, imaging test, hemodynamic test, subsequent intervention, quality of life, cost or cost-effectiveness, death, procedural adverse events), reporting of statistically significant difference between outcomes, and evaluation of predictors of outcomes.

After partial completion of the horizon scan data extraction, it became evident that there exist a large volume of older single arm studies that are of limited relevance today. To conserve available resources, it was agreed to focus our effort on those abstracts that are most likely to be of interest to CMS and to current clinicians. Therefore, for remaining single arm studies published before 2001 we extracted only study type, number of subjects, and interventions.

### TASC II report citations

For each eligible study the following data were extracted: study design; sample size; whether the study was multi- or single center; whether an a priori power calculation was reported; whether adequate allocation concealment was reported; what the clinical classification (Fontaine or Rutherford) of the patients was; what the hemodynamic status of the patients was (primarily ABI); the anatomy (including TASC classification); whether the compared cohorts were comparable at baseline; whether intention-to-treat analyses were performed; whether dropouts were adequately described; whether blinding was performed; the followup time; the results (focusing primarily on whether one intervention performed better than another) for clinical improvement, hemodynamic status, imaging and patency, amputation, mortality, reintervention, and complications; and the study quality and applicability (see below).

### Systematic review of TASC classification

For eligible studies, data were extracted separately for each relevant cohort of patients. Cohorts of patients were separated based on TASC classification (A, B, A or B – if separate data were not available for A and B, C, D, and C or D – if separate data were not available for C and D), intervention, and artery. For each cohort the following data were extracted: the study design, followup time, intervention (bypass, PTA alone, PTA with or without stent, stent (all), endarterectomy, medical, or other), whether results data were reported per patient or per limb, the artery (aorto-iliac, femoral popliteal, tibial, or combination), the TASC classification, the percent of patients in the cohort who had the given TASC classification, and the number of events and patients at risk for each outcome. If a study reported separate data for more than one TASC classification, but one or more groups of patients had fewer than 10 patients, that cohort was omitted. Where data were extracted from time-to-event (survival) curves, we assumed that all patients evaluated at time zero were also available at the time point of interest. We preferentially extracted results at 12 months, since this was the most commonly reported time point.

### Systematic review of stents

For the systematic review of the eligible full articles (comparative studies of stents), we extracted data on study year, country, setting, funding source, study design, dates of procedures, timing of endpoints, eligibility criteria, details of stent, comparator, and cointerventions, definitions of outcomes, subject characteristics, and baseline and final results for outcomes of interest. For RCTs, we evaluated whether the method of randomization and allocation concealment were adequate, whether patients and outcome assessors were blinded, whether results were analyzed on an intention-to-treat basis, whether groups were similar at baseline, and dropout rate. For nonrandomized studies, we extracted whether adjustments for severity of PAD were made and dropout rates. We extracted data for time points closest to 12 months, for the longest time point at which at least 10 subjects per arm were evaluated, and for procedural complications within 30 days. All complication (adverse event) data were extracted exactly as reported.

## Quality Assessment

We assessed the methodological quality of each study in the systematic review of stents based on predefined criteria. We used a 3-category grading system (A, B, C) to denote the methodological quality of each study. This grading system has been used in most of the previous evidence reports from the Tufts EPC as well as in evidence-based clinical practice guidelines.44,45 This system defines a generic grading system that is applicable to varying study designs including randomized and nonrandomized comparative trials, cohort, and case-control studies. For RCTs, we mainly considered the methods used for randomization, allocation concealment, and blinding as well as the use of intention-to-treat analysis, the report of dropout rate and the extent to which valid primary outcomes were described, as well as clearly reported. Studies were not rejected due to poor quality. Studies that are of overall good or fair quality, but poorly report or analyze specific outcomes, or have other problems with those outcomes (such as few patients analyzed), could be given different quality grades for different outcomes.

A(good)

Good quality studies are likely to have the least bias and results are considered valid. They include studies that adhere most closely to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.

B (fair)

Fair quality studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.

C (poor)

Poor quality studies have significant bias that may invalidate the results. These studies have serious problems in design, analysis, or reporting; have large amounts of missing information, large dropout rates, discrepancies in reporting, or other major sources of bias. All retrospective studies were graded C.

## Applicability Assessment

Applicability addresses the relevance of a given study to a population of interest. Every study applies certain eligibility criteria when selecting study subjects. Most of these criteria are explicitly stated (e.g., disease status, age, comorbidities). Some may be implicit or due to unintentional biases, such as those related to location (e.g., multicenter versus single center, intensive care versus all inpatients), year of procedure, and other issues. The applicability of a study is dictated by the key questions, the populations, and the interventions that are of interest to this review, as opposed to those of interest to the original investigators.

For the systematic review of stents, we categorized studies within a target population into 1 of 3 levels of applicability that are defined as follows:

High | Sample is representative of Medicare population in relevant settings. Patients’ age (older adult), gender, spectrum of disease severity and type, etc. are representative of population of interest. No substantial exclusion criteria that would make the sample atypical of patients with PAD receiving invasive interventions.
Moderate | Sample is an important subgroup of population of interest. Possibly limited by a narrow or young age range, type of disease, gender, restrictive eligibility criteria, etc.
Narrow | Sample represents only a narrow, atypical subgroup of population of interest.

## Data Synthesis

### Horizon scan

We primarily evaluated frequencies of occurrence of variables of interest, with subgroup frequencies based on study design. For continuous variables, we calculated medians and interquartile ranges (25^th^ and 75^th^ percentiles). To summarize the data, we created tables by type of study design, type of vascular procedure and by other variables of interest. We also report in the tables, in addition to the number of studies in which we based the summary statistics, the total number of subjects included by type of intervention and type of study design. We noted when analyses included the limited data from single arm studies (due to partial data extraction of the older studies).

We explored graphically the changes in the number of studies of different research designs over time (single arm, RCT, nonrandomized comparative and systematic reviews) using frequency line plots. We constructed similar graphs for the number of published papers per intervention, and per type of artery over time. The graphs do not include 2007 publications because the search does not include all papers published during 2007. For better visualization, time was split into 3-year intervals starting backwards from 2006 (inclusive).

### TASC II report citations

Descriptive analyses were performed to evaluate the level and strength of evidence cited for each TASC II recommendation.

### Systematic review of TASC classification

Graphical analyses were employed. The intent was to create a graph of the TASC data for each outcome, but there were insufficient data for quality of life, so this graph was omitted. For each outcome, the event rates were plotted against the TASC classification (A, B, A or B, C, D, C or D) with separate subcolumns for the intervention types bypass, PTA without stenting, PTA with primary or elective stenting, and other (endarterectomy, atherectomy, or cryoplasty). The different arteries treated were noted by different symbols. Data from cohorts of patients with the same treated arteries who were in the same studies were linked by connecting lines. When studies reported results at multiple followup times we preferentially used 12 month data. We excluded from the graphs event rates based on fewer than 10 patients (for each intervention-artery-TASC combination in each study), or when the followup length was less than 6 months.

We use these graphical analyses to summarize the observed event rates as reported in the literature. In addition, we summarized in details the relevant findings of studies that either directly compared interventions within a single TASC classification or directly compared TASC classifications.

### Systematic review of stents

#### Summary tables and outcome metrics used

For each outcome reported by more than one study, we summarized data in summary tables which include data on study design characteristics, subject characteristics, category of stent type, crossover rates, number of subjects analyzed, results data, quality, and applicability. For continuous outcomes we included baseline values, final values, and net differences (change in stent arm minus change in control arm). Where necessary, confidence intervals (CI) of the net differences were estimated from the reported data. Because event rates were low for most outcomes we report risk differences (RD), calculated from the raw data, because odds ratios (OR) cannot be estimated when there are no events. For changes in clinical status, we report OR. For rates of reinterventions (repeat procedures) there was a wide range of event rates. We reported both OR and, because event rates were very low in some studies, RD.

#### Metaanalyses

Metaanalysis was performed to examine whether therapeutic management based on stent insertion led to improved patient outcomes compared to PTA, when there was sufficient clinical or statistical homogeneity to allow for a meaningful summary estimate. We restricted metaanalysis to RCTs to avoid performing analyses of mixed design types and because the inherent biases of nonrandomized studies suggest that they should be used only to support the randomized data or to suggest reasons for heterogeneity. Furthermore, the small number of nonrandomized studies that evaluated similar interventions and outcomes precluded meaningful metaanalysis.

##### Main Analyses

For the main analyses, we used DerSimonian and Laird’s random effects model for syntheses.46 The random effects model assigns a weight to each study based both on the individual study variance and the between-study heterogeneity. Compared with the fixed effect model, the random effects model is more conservative in that it generally results in broader confidence intervals when between-study heterogeneity is present. We tested for heterogeneity using Cochran’s Q and assessed its extent with I2, which evaluates the proportion of between study variability that is attributed to heterogeneity rather than chance.47 In the case of sparse events (<5 percent), we instead used the Peto method to derive summary estimates for metaanalysis of odds ratios.48

##### Subgroup Analyses

To explore potential reasons for differences of results across studies, we performed subgroup analyses by overall methodological quality, and type of artery for all metaanalyses (as applicable). Because of the small number of trials per metaanalysis, extensive subgroup analyses were not feasible.

##### Sensitivity Analyses

Trials with no events in both arms pose (technical) difficulties in the calculation of effects sizes for binary outcomes, necessitating the addition of a “fudge factor” to the raw counts. Some methodologists suggest excluding such studies from metaanalyses 48,49. Therefore, for all metaanalyses where at least one study had 0 events in both arms, we performed two sensitivity analyses, We repeated the main analyses excluding all studies with 0 events in both arms and we performed Mantel-Haenszel fixed effects metaanalyses, as suggested elsewhere 48,49.

##### Software

All analyses and graphs were performed in Intercooled Stata 8.2 (Stata Corp, College Station, TX).

## Handling Multiple Publications of Studies

Some trials have multiple publications. As a result, data on some outcomes were reported in different publications for different study endpoints (times). Each study, regardless of the number of publications, was treated as a single entity. We thus had to pick and choose among the articles for those data that best conformed to the data of interest to this report. We attempted to use the descriptions of study design, interventions, outcomes, etc. that were most complete. For simplicity, we referenced all the publications related to the same trial once in the introductory section for each outcome but only referenced a single publication from the same trial in the subsequent sections for each outcome.