# Introduction

Note: The introduction is not based on a systematic review of the evidence. It is based on the best information available to us at the time of writing.

## Rising prevalence of peripheral arterial disease (PAD)

About 12 million people in the United States have peripheral arterial disease (PAD) and this number is projected to increase to 16 million by 2030.^1,2^ In an asymptomatic population, the National Health and Nutritional Survey found that the prevalence of PAD in the 50–59 age group was 2.5%, while it was 14.5% among those over age 70.^3^ Several factors contribute to the projected rise in prevalence: 1) the aging of the population, 2) an increase in the incidence of diabetes, an important risk factor for PAD, and 3) improved surveillance for PAD. The rise in the prevalence of PAD is likely to occur despite efforts at modifying some risk factors (such as cessation of the use of tobacco products and various treatments of lipid abnormalities) in the face of worsening of other risk factors (such as rising rates of diabetes and obesity). Among people with PAD, lower extremity atherosclerosis was the most commonly treated anatomic area in 1980 with 111,560 procedures or 49 per 100,000 people.4 Since then, there has been more than a 50 percent increase in the number of vascular procedures per capita from 182 per 100,000 in 1980 to 284 per 100,000 in 2000.^4^

## Classification of PAD

The Society for Vascular Surgery (SVS) recognized the need for standardization of reporting methods to define the clinical severity of PAD and standards for reporting the results of treatment. Rutherford chaired a committee which produced a clinical classification system that is based on increasing severity of disease (Table 1).5 Fontaine had earlier published an alternative classification system (Table 1), which is employed by many European physicians.6 Both these clinical classifications allow investigators to compare the preoperative status of patients within various studies to other studies and to gauge the effect of therapy on an individual patient’s clinical state.

Clinical classification categorizes patients by: 1) the degree of limitation in walking due to claudication; 2) rest pain; or 3) the amount of tissue loss associated with their PAD, irrespective of its anatomic site. These clinical symptoms are usually related to the degree of ischemia produced and therefore the extent of atherosclerotic blockage within the lower extremities, including the length, number and location of lesions, as well as the degree of stenosis.7 The degree of clinical ischemia and the patient’s symptoms influences the choice of interventions, when balanced against their risks. Rutherford and Becker developed reporting standards for endovascular therapy, which provided objective criteria to classify the severity of the disease and degree of improvement following this therapy.8

### Diagnostic testing

Objective hemodynamic classification of the functional status of the limb has been in use for several decades. It has been incorporated into the clinical classifications and reporting standards for PAD (Table 1).5 Several studies have correlated the clinical status of the limb with the degree of hemodynamic impairment, as measured by Doppler pressures.9 Continuous wave Doppler measurements of the arterial pressure – the pressure at which the first pulse in the Doppler-scrutinized vessel is heard – has become the standard of care for establishing the hemodynamic status of a limb.

Table 1 SVS (Rutherford) and Fontaine classifications and criteria for PAD

Clinical | [underlined: Fontaine] | | | [underlined: SVS (Rutherford)]
Clinical | Stage^*^ | Grade | Category | Further Clinical Description | Objective Criteria
Asymptomatic | I | 0 | 0 | No hemodynamically significant occlusive disease | Normal treadmill or reactive hyperemia test
Mild Claudication | IIa | I | 1 | | Completes treadmill exercise; Ankle pressure after exercise >50 mm Hg, but ≥20 mm Hg lower than resting value
Moderate Claudication | IIb | I | 2 | | Between categories 1 and 3
| IIb
Severe Claudication | IIb | I | 3 | | Cannot complete treadmill exercise and ankle pressure after exercise <50 mm Hg
Ischemic Rest Pain | III | II^†^ | 4 | | Resting ankle pressure <40 mm Hg, flat or barely pulsatile ankle or metatarsal pulse volume recording; Toe pressure <30 mm Hg
Minor Tissue Loss | IV (ulceration or gangrene) | III^†^ | 5 | Nonhealing ulcer, focal gangrene with diffuse pedal ischemia | Resting ankle pressure <60 mm Hg, flat or barely pulsatile ankle or metatarsal pulse volume recording; Toe pressure <40 mm Hg
| IV (ulceration or gangrene) | | | | Resting ankle pressure <60 mm Hg, flat or barely pulsatile ankle or metatarsal pulse volume recording; Toe pressure <40 mm Hg
Major Tissue Loss | IV (ulceration or gangrene) | III^†^ | 6 | Extending beyond transmetatarsal level, functional foot no longer salvageable | Resting ankle pressure <60 mm Hg, flat or barely pulsatile ankle or metatarsal pulse volume recording; Toe pressure <40 mm Hg

Inter-Society Consensus for the Management of PAD (TASC II). J Vase Surg. 45(Suppl S): S29A. 2007

* The Fontaine stages defined by TASC II differ somewhat from Fontaine’s original staging.6

† Critical limb ischemia

Ankle pressure or the ankle-brachial index (ABI, the ratio between ankle and brachial systolic blood pressures) has become the standard test used to estimate the severity of arterial disease. However, patients with claudication, but without flow- or pressure-reducing stenosis at rest, may have normal ABIs at rest. In this case, the patient usually undergoes a treadmill exercise test at a standardized incline (grade) and rate of speed for usually five minutes or until pain develops. The maximum walking time or maximal walking distance is recorded and may be further qualified as maximal pain-free time or distance. These values have good reproducibility and are clearly clinically relevant. In addition, ankle pressures are measured immediately after exercise.10 The percent decrease in post-exercise pressure reflects a proximal stenosis as well as the degree of collateral vessel formation.11

The specific anatomic site of disease has been defined traditionally by catheter-based arteriography, but computerized tomographic angiography, magnetic resonance angiography and duplex ultrasonography are now used not only to determine the extent of disease across vessels, but also its luminal encroachment. Treatment choices (endovascular versus open surgery) can be made based on computerized tomographic angiography in the majority of patients.12

### Anatomic Levels of Involvement

Lower extremity PAD spans three traditional anatomic areas of disease: 1) aorto-iliac segment 2) femoral popliteal segment and 3) infrapopliteal segment (also called the infrageniculate segment). When two or three anatomic segments are involved this condition is termed “combined segment disease ”, which commonly involves both the aorto-iliac and femoral popliteal segments. The patient’s clinical status is usually more advanced in this latter situation.13 The clinical relevance of the anatomic classification is based on the difference at each site in hemodynamic characteristics, vessel diameter, and the anatomic site’s specific predilection for atherosclerosis.7 The natural history without therapy appears to differ for each site.14 For example, aorto-iliac stenosis with claudication has a relatively “benign” natural history, while occlusive tibial disease may not. Moreover, PAD is an important marker for the concomitant presence of coronary artery disease and carotid artery disease, which has a more morbid natural history. Indeed, the five year mortality of a typical patient with claudication is 30 percent, the major cause of deaths being due to cardiovascular disease.15 An additional 5 to 10 percent will sustain a nonfatal cardiovascular event. Both the attitude toward intervention and the response to intervention have classically depended on the anatomic site as well as clinical symptoms. In the past these attitudes were influenced by natural history studies as well as case series on open surgical intervention. Clearly, the morbidity of an open surgical procedure and the possibility of death balanced against its benefits weighted intervention toward more limb threatening situations or severe claudication. Endovascular treatment with both its lower morbidity and chance of death has expanded the number of patients undergoing treatment for PAD. The question remains regarding how various treatment options compare for PAD in different anatomic areas of disease.

## Treatment options

### Open surgery in the lower extremity

Because of its historical relevance as the first intervention available, open surgery is discussed first. Earlier angiographic studies by Coran and Warren suggested that the femoral popliteal segment at the adductor canal (just above the popliteal artery) is the most common site for atherosclerosis in the lower extremity,16 but the aorto-iliac bifurcation may be the earliest area of atheromatous involvement. In the past, treatment by open surgery for lesions in the femoral popliteal segment was reserved for patients with severe limiting claudication or chronic limb ischemia (as evidenced by rest pain or tissue loss). In patients with infrapopliteal PAD, surgery was reserved for patients with chronic limb ischemia. By contrast, surgery for aorto-iliac disease was used in patients with less severe claudication, despite the greater risks of open treatment of these arteries, because of the more durable long-term results with this approach compared to that with surgery in other segments.17 The risk-benefit ratio of open surgery weighted the decision toward conservatism, because of the real mortality and morbidity of open vascular reconstruction. The current American College of Cardiology (ACC) and American Heart Association (AHA) consensus recommendations are to select surgery for patients with claudication only when “significant” vocational or lifestyle limitations are present and only after exercise or pharmacologic treatment has failed. These attitudes toward intervention, however, have been modified greatly by the availability of lower risk catheter-based techniques.

Surgical bypass is most commonly performed with an autogenous (the patient’s own) saphenous vein and is the recommendation of both the Transatlantic Intersociety Consensus (TASC) II and ACC/AHA consensus documents. Synthetic grafts are reserved for absent or poor quality vein, particularly when employed to the below-knee popliteal or tibial arteries.18 Successful infrainguinal bypass has been associated with resolution of symptoms, as well as a 5 year patency rate of 70 to 80 percent in the femoral popliteal segment19 and a 60 to 70 percent patency rate in the tibial segment20 in cohorts of patients. Open superficial femoral artery endarterectomy had been abandoned for the better durability of femoral popliteal autogenous vein bypass, but has enjoyed utility as a strategy to spare the saphenous vein for later use.21 Endarterectomy in this segment has been revived by the development of a less invasive approach (remote superficial endarterectomy, which is still an open approach through the common/proximal femoral artery) where the intima and atherosclerotic disease of the entire superficial femoral popliteal segment is removed through a single femoral incision.22,23 This technique, which is popular in Europe, has been employed in longer lesions, i.e., TASC C and D lesions. Recent reports emphasize the need for surveillance to detect restenosis due to neointimal hyperplasia, which may be treated by PTA.23,24. A recent systematic review of case series concluded that this approach had acceptable short and long term results, but emphasized the need for non-invasive surveillance and proper RCTs.25

The TASC II recommendations and usual clinical practice for selection of an open approach are apparently not based on any randomized controlled trials (RCTs) that compare surgical bypass to best medical treatment (or no treatment). The recommendations for surgical bypass are based on cohort studies, often retrospective.26 On the other hand there are several RCTs that compare autogenous vein to synthetic grafts or synthetic to synthetic grafts.18 However, as will be discussed further below, the majority of these studies, particularly the earlier studies, customarily focused on graft patency rather than clinical outcomes. Notably though, the standard length of followup for graft patency has been five years following the recommendation of Szilagyi.27 Shorter term followup was not felt to reflect the true durability of the surgical procedure. Indeed, one of the first multicenter RCTs, which compared autogenous vein to synthetic grafts for infrainguinal disease, showed comparability of patency at 2 years between vein and synthetic grafts, but a reduced patency rate for the synthetic graft arm at 5 years.18 This longer followup period is related to the increased risk of death and higher morbidity with open techniques and the need to justify this risk. Shorter followup periods are reported in trials of catheter-based techniques, in part due to the procedures’ lower morbidity and mortality.

For occlusive disease involving the aorta, a synthetic bypass (either polyester [Dacron] or polytetrafluoroethylene [PTFE]) is sewn in at the infrarenal aorta level (proximal anastomosis) and another at both femoral arteries (distal anastomosis) beyond the area of iliac stenosis, or more usually occlusion. Aorto-femoral bypass has been the surgical procedure of choice for this segment and had supplanted aorto-iliac endarterectomy (removal of the inner lining of the artery and atherosclerotic plaque), because of the propensity of the latter for the development of neointimal hyperplasia and occlusion. Aorto-femoral bypass has produced durable symptom relief and a patency rate at 5 years of 85 percent for patients with claudication and 80 percent for patients with chronic limb ischemia.28 Again the data supporting this approach is derived from numerous and large case series rather than RCTs.

### Endovascular procedures

It is projected that the number of patients undergoing arterial revascularizations will increase 19 percent from 2005 to 2010.^1^ Overall catheter-based interventions for lower extremity PAD have risen from 0.1 per 100,000 population in 1980 to 58.3 per 100,000 in 2000.^2^ An analysis of the National Inpatient Sample data found that while open lower extremity procedures decreased by 30 percent from 1996 to 2003, endovascular procedures in this segment rose by over 40 percent per capita.4 Catheter-based techniques, thus, are one of the principal drivers of the increased volume of revascularizations. The key driver of this growth is the less invasive nature of endovascular treatments, which is associated with both lower mortality and morbidity. Vascular specialists have become quite comfortable in treating high-grade stenoses or short segmental occlusions of the iliac artery with an endovascular approach and techniques for longer occluded segments are being further refined. Percutaneous transluminal angioplasty (PTA) and stents are the two principle and primary techniques employed in endovascular therapy. Alternative treatments, such as subintimal angioplasty or covered stents, are modifications of PTA or stenting that expand applicability of the principle techniques. Drug-eluting stents, brachytherapy and cryoplasty have also been developed to reduce neointimal hyperplasia. Devices that remove plaque, such as the atherectomy catheter, may be used primarily or as an adjunct to the two basic techniques. Evidence supporting these alternative treatments is less robust than for PTA and stenting.

Over 40 years ago, Dotter and Judkins introduced the concept of “transluminal treatment of arterial sclerotic obstruction” as a catheter-based technique for relieving atherosclerotic stenosis, in order to reduce morbidity and mortality in patients with concomitant coronary artery disease.29 Gruntzig subsequently developed a polyvinyl rigid sausage-shaped balloon on his kitchen table; not unlike De Bakey’s sewing machine manufacture of the first aortic synthetic grafts.30 Gruntzig successfully dilated a superficial femoral artery stenosis associated with claudication in 1974 and a patient with an iliac artery stenosis one year later with his double lumen catheter. Commercial availability of these devices with modifications has led to the rapid adoption of endovascular approaches. Since then, particularly over the past 10 years, endovascular therapy has exploded in volume and created a tectonic shift in the way patients with PAD are managed.

Endovascular revascularization currently includes several techniques: 1) PTA, 2) arterial stenting, and 3) various adjunctive techniques such as atherectomy. The most recent major catheter-based development in the treatment of the PAD is peripheral stenting, which is a rapidly evolving technology. It has been used extensively in the past decade since publication of the first systematic review on the topic.31 Stenting is generally performed to correct a suboptimal PTA, where there is a flow-limiting dissection or residual stenosis that reduces the lumen (usually by 30 percent), termed secondary stenting. Stenting allows avoidance of surgery and, in such cases, the stent is placed for residual stenosis or if there is a flow-limiting dissection. Stents are used primarily when an occlusion is being recanalized, particularly a lengthy one, or when performing a subintimal balloon angioplasty. PTA alone, however, may still be the first choice for segments involved by PAD of a relatively short length (TASC A), such as the superficial femoral artery segment. The TASC II recommended approach for aorto-iliac disease and, it appears, femoral popliteal disease is PTA with secondary stenting if needed for suboptimal results or acute occlusions. It should be emphasized that TASC II recommended PTA as “the procedure of choice” for limited disease stenoses or occlusions less than 10 cm in the femoral popliteal segment. However, primary stenting in all patients receiving angioplasty is more common for longer lesions, such as TASC C stenosis or occlusion of at least 15 cm length.

Although the mechanism of PTA was initially believed to be related to a controlled inflation of an intraluminal balloon to widen the arterial lumen by compressing the atherosclerotic plaque into the arterial wall, it is now clear that deep fractures in the intima with concomitant medial dissection and stretching is the actual mechanism leading to an increase in the lumen diameter.32 In essence PTA involves a controlled stretch injury of the media without rupturing the adventitia. The complication of vessel rupture, which is unusual in experienced hands, is avoided by the correct matching of the balloon size to the lumen diameter. The major risks of angioplasty include bleeding due to arterial rupture, embolization due to fragmenting the plaque material, and arterial dissection. Remodeling of the vessel wall generally occurs, which allows the lumen to remain patent. However, early restenosis can occur due to intimal hyperplasia or vessel wall recoil as opposed to what is observed in surgical endarterectomies; whereas late restenosis is due to the same processes that caused the original stenosis.

Cryoplasty combines PTA with the application of cryothermal energy to the arterial wall, which induces aptosis of smooth muscle cells and programmed cell death. The primary aim of this method is to prevent or treat restenosis and has been employed as a primary endovascular technique. Mid-term evaluation of results as a primary therapy, which had been initially promising, have shown significant decrements in patency.33 This technique had been advanced as a method to minimize the formation of neointimal hyperplasia, which occurs after PTA alone and had been considered to be an advantage in instances of restenosis, though a Cochrane review failed to show any advantages over conventional angioplasty.34

The long-term results of PTA in the superficial femoral artery have been affected by a restenosis rate of approximately 40 percent and do not match results achieved in other sites. The femoral popliteal segment places special demands on endovascular treatment due to the unique anatomy (its being a long artery without major collateral vessels), structural mechanics (subject to rotational and longitudinal compressive forces), and hemodynamic features (low flow with a high resistance run-off bed) of these arteries. The placement of a metallic stent may improve these results. Stents may have particular advantages in lengthy occlusions. There are two basic types of stents, balloon- and self-expandable. Balloon-expandable stents employ an angioplasty balloon to expand and set the stent within the arterial segment. The Palmaz stent is an example of this type, though it has been supplanted by the next generation of self-expandable stents for arterial occlusive lesions. Self-expanding stents may have benefits in longer occlusive lesions as primary therapy, particularly in the femoral popliteal segment, where PTA and balloon expandable stents may be associated with higher rates of restenosis and failure. The self-expandable stent depends on the unique properties of a memory metal, such as nitinol, or alternatively the weave of the stent, to assume a preconfigured shape within the vessel lumen. Wallstents, an example of the latter are composed of elgaloy, a variant of stainless steel, and the radial force induced by the weave density determines expansion. Self-expandable stents may be post-dilated to ensure strut apposition to the arterial wall. The patency rates of these stents appear to be superior to the balloon expandable stent.

In addition, newer materials have been added to the stents with the goal of improving their clinical effect. The standard stent, whether balloon- or self-expandable, is bare metal, with no added materials. Covered stents employ a synthetic fabric, such as PTFE, that covers the metal component of the stent and acts as an exoskeleton. However, animal studies did not support the proposed advantage of the covered stent, that it lowers the incidence of neointimal hyperplasia, which can hasten restenosis.35 While the incidence of neointimal hyperplasia was reduced in the midportion of the graft it was comparable to controls at the proximal and distal ends of the covered stent. One major advantage of a stent graft is that a longer infrainguinal lesion can be treated. In theory, the synthetic fabric of the covered stent excludes the atherosclerotic plaque from the lumen. In addition, there may be formation of a more stable layer from tissue ingrowth, which may be related to the specific “pore” size of the PTFE material may occur. Moreover, the combination of the nitinol exoskeleton and the fabric cover yields a flexible, but structurally stable device, which is particularly advantageous in the femoral popliteal segment.

However, fracture of the stent’s metal struts may be an inherent problem to stent performance and some have suggested it has been associated with stent failure.36 Device failure due to a stent fracture is a particular problem in the distal superficial femoral and proximal popliteal arteries, due to the unique mechanical forces (longitudinal bending and torquing) exerted on stents in this area. Scheinert and colleagues described a 37 percent incidence in their plain radiography survey of 121 treated legs.37 They conclude that stent fracture risk increased with long segment stenting and that the primary patency was lower in those limbs with stent fractures (41% versus 84%; P<.0001). Schlager and associates compared the rates of in stent restenosis, stent fractures and clinical worsening in patients under going placement of either 116 Wall Stents or nitinol stents (45 SMART stents and 125 DYNALINK stents) in the superficial femoral artery.38 The rate of stent fractures were 19 percent over 3 years; 28 percent for SMART stents and 2 percent for Dynalink/Absolute stents. The clinical deterioration paralleled the stent fracture findings. Irrespective of clear linkage to restenosis, Jaff et al, in 2007, have recommended that a standardized method of surveillance for stent fracture is required, which takes into account among many variables the types of radiographic equipment and imaging techniques.39

Drug-eluting stents, designed for the coronary circulation, have been applied to peripheral vascular lesions. This is an example of an “off label” use, as discussed below. These stents commonly contain sirolimus (rapamycin), an immunosuppressant drug used to prevent neointimal hyperplasia. Other treated stents have been developed including the Carbostent, which has a thin coating of carbon meant to decrease its interaction with platelets.

“Off label” use of stents intended for the biliary tree (special weave configuration) or coronary vessels (drug coated) is common in peripheral arteries. Arguably, this is a problematic development because the device does not follow the usual FDA approval pathways. In the US, the safety of these devices is tracked through obligatory reporting in the Manufacturer and User Facility Device Experience (MAUDE) database. However, the self-reporting nature of the databases makes it difficult to validate actual incidence rates of problems with these devices. Additional RCTs are underway, one which compares PTA alone to PTA and a biliary stent in the superficial femoral and proximal popliteal arteries; another RCT has been performed, which examines a bare nitinol biliary stent in the same anatomic segment. Neither of these trials has yet been published in peer-reviewed journals at the time of our review.

An alternative approach to PTA or stenting is the atherectomy catheter, which removes the atherosclerotic plaque from the lumen, thereby remodeling a narrowed lumen to a nonstenotic flow stream. Frequently, this technique is used as an adjunct with arterial stenting

### TASC and ACC/AHA Practice Guidelines

In 2000, the Transatlantic Intersociety Consensus (TASC) Committee was formed, representing 14 societies including vascular surgery, interventional radiology, angiology and cardiology. The original recommendations were published in that year.15 In 2007, the working group was expanded to 16 societies from additional countries; it published an update of the consensus document.26 These documents have had an important impact in the field as they represent a consensus among the various specialties that treat PAD. They also provide a clear standardization by anatomic description of the extent and degree of disease in both the aorto-iliac and femoral popliteal segments. Table 2 summarizes the TASC classification and treatment recommendations for aorto-iliac and femoral popliteal segments. The TASC committee used this anatomic classification system to make recommendations on the type of treatment (endovascular versus open surgical) based on the anatomic nature and extent of the lesions. However, as discussed in more detail below, the evidentiary basis for recommending treatment type based on TASC classification is unclear.

The American College of Cardiology (ACC) and The American Heart Association (AHA) convened a task force of cardiologists, vascular medicine specialists, interventional radiologists, and vascular surgeons to develop guidelines for PAD. Their important recommendations are published in Circulation 2006 and are available on line (www.acc.org or www.americanheart.org). These recommendations are based on “Level of Evidence”: Level A, data from multiple RCTs or metaanalyses; Level B, data from single RCTs or nonrandomized studies; and Level C, consensus of experts, case studies, or standards of care. The Recommendations were also divided into descending grades: Class I, general agreement that the treatment is beneficial, useful and effective; Class II, conflicting evidence or divergence of opinions on the utility of the treatment; and Class III, evidence of no benefit or utility. The document recommends general methods for assessing PAD based on its severity, anatomy, as well as the type of intervention appropriate to clinical symptoms and anatomic involvement, or “morphological characteristics.” Risk factor modification is emphasized.

Table 2 TASC classifications and treatment recommendations for aorto-iliac and femoral popliteal lesions26

Classification | Definition | | Treatment Consensus
Classification | Aorto-Iliac Lesions | Femoral Popliteal Lesions | Treatment Consensus
TASC A | - Unilateral or bilateral stenoses of CIA; - Unilateral or bilateral single (≤3 cm) stenosis of EIA | - Single stenosis ≤10 cm in length; - Single occlusion ≤5 cm in length | Endovascular therapy is the treatment of choice
TASC B | - Short (≤3 cm) stenosis of infrarenal aorta; - Unilateral CIA occlusion; - Single or multiple stenosis totaling 3–10 cm involving the EIA not extending into the CFA; - Unilateral EIA occlusion not involving the origins of internal iliac or CFA | - Multiple lesions, each ≤5 cm (stenosis or occlusions); - Single stenosis or occlusion ≤15 cm not involving the infrageniculate popliteal artery; - Single or multiple lesions in the absence of continuous tibial vessels to improve inflow for distal bypass; - Heavily calcified occlusions ≤5 cm in length; - Single popliteal stenosis | Endovascular is the preferred treatment. The patient’s comorbidities, fully informed patient preference, and the local operator’s long-term success rates must be considered when making treatment recommendations.
TASC C | - Bilateral CIA occlusions; - Bilateral EIA stenoses 3–10 cm long not extending into the CFA; - Unilateral EIA stenosis extending in the CFA; - Unilateral EIA occlusion that involves the origins of internal iliac and/or CFA; - Heavily calcified unilateral EIA occlusion with or without involvement of origins of internal iliac and/or CFA | - Multiple stenoses or occlusions, totaling >15 cm, with or without heavy calcification; - Recurrent stenosis or occlusions that need treatment after two endovascular interventions | Surgery is the preferred treatment for good-risk patients. The patient’s comorbidities, fully informed patient preference, and the local operator’s long-term success rates must be considered when making treatment recommendations.
TASC D | - Infrarenal aorto-iliac occlusion; - Diffuse disease involving the aorta and both liac arteries requiring treatment; - Diffuse multiple stenoses involving the unilateral CIA, EIA, and CFA; - Unilateral occlusions of both CIA and EIA; - Bilateral occlusions of EIA; - Iliac stenoses in patients with AAA requiring treatment and not amenable to endograft placement or other lesions requiring open aortic or iliac surgery | - Chronic total occlusion of the SFA (>20 cm, involving the popliteal artery); - Chronic total occlusion of the popliteal artery and the proximal trifurcation vessels | Surgery is the treatment of choice

AAA, abdominal aortic aneurysm; CFA, common femoral artery; CIA, common iliac artery; EIA, external iliac artery; SFA, superficial femoral artery.

The TASC II document summarizes the principles that are employed by most vascular specialists: 1) balance the risks of the procedure to the benefits; and 2) assess the durability and amount of improvement that can be expected from that specific procedure.26 The important classification of the morphology of the atherosclerotic involvement of the aorto-iliac and femoral popliteal segments depends on the location within the segment (e.g., common versus external iliac), stenosis versus occlusions, and the length of the lesion. The degree of calcification is not included. For both the aorto-iliac and femoral popliteal segments, endovascular intervention is the therapy of choice for TASC A lesions and is preferred for TASC B lesions or high risk patients with TASC C lesions, while surgery is recommended for TASC D lesions and “good” risk patients with TASC C lesions. Selection of the approach also depends on patient’s preference and the individual treating physician’s long term results.

In the ACC/AHA consensus document indications for endovascular treatment are based on the clinical symptoms and anatomic level. The level of evidence is provided as documented in the guidelines. PTA is indicated for patients with TASC A claudication and aorto-iliac disease. Stent placement is restricted to those patients who have either a suboptimal or failed result following PTA. Although the evidence for primary stenting of a common iliac and external iliac artery lesion is rated level B for common iliac lesions and C for external iliac artery disease, primary stenting is termed a Class I recommendation. For patients with femoral popliteal lesions PTA again is recommended as the initial endovascular treatment and the effectiveness of stents as well as other techniques is rated Class lib with an A level of evidence. Similar to recommendations for the management of iliac disease, primary stent is not recommended as the primary treatment for femoral popliteal disease. Stents should be employed secondarily for a failed PTA. Chronic limb ischemia is discussed in brief and no apparent specific recommendations for endovascular treatment are given for these patients. The majority of the recommendations discuss surgery for chronic limb ischemia.

## Outcomes evaluated in PAD intervention studies

Patency has been the standard method for assessing the efficacy of a vascular surgical intervention. Raw patency measures (e.g., number of patent grafts /number of grafts at risk) had been replaced by life table analysis of graft patency, which accounts for grafts lost to occlusion, subjects lost to followup or to death, and was modeled after survival data employed in oncology. Unfortunately with bilateral procedures investigators have employed the surgeon’s perspective of limbs at risks rather than the patients’ perspective of people at risk. This convention has continued into the assessment of catheter-based techniques. A further refinement was the concept of secondary patency to account for successful interventions on a failed or occluded graft.

Patency was originally defined by clinical means; i.e., recurrence of primary symptoms or loss of pulse. More recently, trials of catheter-based interventions have employed imaging criteria for patency and have further modified this outcome measure to include deterioration of morphologic status from a less than 10 percent stenosis at the treated site to a 50 percent or greater stenosis as determined by Duplex ultrasound peak systolic velocities 2 cm proximal to the suspected lesion (prestenotic), within the lesion (intrastenotic), and up to 4 cm distal to the lesion (poststenotic) to derive a ratio and percent stenosis. Binary restenosis has been customarily defined as a ratio greater than 2.4.^40^ However, it is important to understand that patency is a surrogate outcome for a presumed accompanying change in clinical status. In the later form, restenosis or “loss of patency” is intended to provide earlier information on the durability of the intervention and the eventual recurrence of symptoms. Reintervention may be chosen to prevent failure and the clinical status of the patient may not change. Patency is deep-rooted in the vascular literature as an outcome and many studies do not report more robust outcomes like improvement and maintenance of clinical status. As part of the reporting standards projects in vascular disease commissioned by SVS, Rutherford and associates developed outcome measures that do report clinical status as a criteria for efficacy of a vascular intervention.5 Commenting the Schillinger 2006 trial, which compared PTA to nitinol stenting, Hirsch called for studies to include meaningful clinical endpoints, such as: 1) for patients with claudication, quality of life questionnaires and treadmill testing; and 2) for critical limb ischemia, complete wound healing, resolution of pain and limb salvage (absence of amputation).41

The TASC II document stresses that for the evaluation of treatment of claudication, a “patient-based outcome assessment…is the most important measure,”26 based on the work of Dormandy and associates.42 For chronic limb ischemia, a “primary outcome would be amputation-free survival.”26

A recent international consensus document highlighted the problems of outcomes reporting in endovascular trials and focused on the drawbacks of using patency alone as an endpoint.43 As the authors stated, “undoubtedly, clinical success has little correlation with patency of the treated vessel,” The consensus committee ascribed some of the problem to applying a concept – patency, which is employed in describing the results of open surgery – to outcomes following endovascular interventions. In reports of open surgery, assisted primary patency (impending occlusion due to restenosis, which is prevented by a reintervention) or secondary patency (treatment of occlusion, which restores patency by a new intervention) are common outcome measures. By contrast, the results of endovascular procedures depend on defining restenosis within the treated segment. Commonly, the development of restenosis is monitored by duplex ultrasonography, but unfortunately different criteria for “restenosis” have been applied. The authors of the consensus document proposed essential patient characteristics that should be defined-1) baseline clinical, anatomic and demographics; 2) procedural outcomes and complications (harm); and 3) long- term outcomes (at least 12 months), including clinical, anatomic and hemodynamic outcomes. All three outcome measures appeared intertwined without priority given to clinical measures. These recommendations are an important step toward standardizing evaluations of endovascular interventions and as our document will demonstrate that the majority of RCTs fail to employ these reporting characteristics. The goal of this review is to describe “patient-important” outcomes rather than surrogate measures, which may have poor validity. Thus, patency outcomes are not systematically evaluated.

## CMS request

The Centers for Medicare and Medicaid Services (CMS) has requested a technology assessment on invasive interventions to treat occlusive lesions related to PAD, focusing primarily on peripheral artery angioplasty with stent placement. The objective is to describe the types of published studies on invasive interventions for PAD and to address specific questions about the relative safety and effect of peripheral stenting compared to other interventions.

CMS had questions about whether there is evidence from clinical trials about clinical diversity and heterogeneity of lesions affecting different sections of peripheral arteries or, if the effectiveness of interventions varies depending on affected part of the arteries. Stent technology is also evolving rapidly and there are a number of comparative studies of different stents (including drug eluting stents). It is important to appreciate that an earlier generation of stents may have been abandoned by clinicians in favor of newer technology with the promise of improved durability. CMS is specifically interested in clinically important patient outcomes. This includes outcomes that directly relate to patient health and well-being (e.g., death, amputation, quality of life) or that are accepted as adequate surrogates for assessing clinical severity of disease (e.g., ankle-brachial index, walking distance). CMS has requested that surrogate vascular measures that do not assess clinical status (e.g., asymptomatic restenosis found with ultrasonography) while frequently employed as an outcome measure, should not be the focus of this review.

Also of interest is clarification of which features of patients with PAD and of the PAD lesions themselves may differentiate which patients (or lesions) may best benefit from stenting. It is unclear whether categorizing patients or lesions by features other than anatomy (i.e., iliac, femoral, femoral popliteal, popliteal, tibial, etc) would be useful for estimating the balance between effect and safety of the intervention. Thus, determination of specific characteristics, which may include but are not necessarily limited to anatomy, lesion characteristics (stenosis, occlusion, and its length), age, comorbidities, physical status may be helpful in categorizing the different effects of stenting are also of interest to CMS.

## Key questions

1. Perform horizon scan of published literature on invasive vascular procedures for the treatment of infrarenal PAD (surgical bypass grafting, angioplasty, angioplasty with stent placement, atherectomy). Categorize studies based on intervention; preoperative characteristics of PAD defined by clinical, anatomic, and hemodynamic features (based primarily on TASC II classification schemes26); primary outcomes; study design; and sample size.
2. Review and describe the studies cited in the TASC II report26 that support the recommendations regarding choice of intervention. Judge whether the cited studies adequately support the recommendations.
3. Perform a systematic review across invasive vascular interventions for infrarenal PAD for the association between the TASC I or II classification schemes and rates of clinical outcomes (mortality, amputation, clinical stage, reinterventions, and quality of life) after the intervention, accounting for differences in anatomy and interventions.
4. Perform systematic review of the relative safety and effect of peripheral artery stenting with other invasive vascular procedures for occlusive PAD of infrarenal vessels. Also evaluate comparisons of different stents and/or different procedures with stents. Among comparative studies (stent versus other intervention; stent versus stent) evaluate the following questions and features:
  - Methodological quality of studies
  - Applicability of studies to patients aged ≥65 years with occlusive PAD (based on the CMS population)
  - Demographic and other preoperative (baseline) features of studied patients
  - Clinical, anatomic, and hemodynamic features of PAD lesions (based primarily on TASC II classification schemes)
  - Types of the stents used (specifically discussing steel, nitinol, drug eluting and other stents in this rapidly evolving field)
  - Concurrent and postoperative treatments, including but not limited to brachytherapy and antiplatelet therapy
  - Length of followup
  - Persistence of effects over time
  - Clinical outcomes (patient survival, limb salvage, primary patency, primary assisted patency, secondary patency, pain, quality of life)
  - Adverse events