# Comparative Studies and Systematic Reviews in Horizon scan RCTs that evaluate PTA

## RCTs that evaluate PTA

Ahn S, Rutherford RB. A multicenter prospective randomized trial to determine the optimal treatment of patients with claudication and isolated superficial femoral artery occlusive disease: conservative versus endovascular versus surgical therapy. Journal of Vascular Surgery. 1992;15:889-891. UI 1533686. [pmid: 1533686].
Belli AM, Cumberland DC, Procter AE, Welsh CL. Follow-up of conventional angioplasty versus laser thermal angioplasty for total femoropopliteal artery occlusions: results of a randomized trial. Journal of Vascular & Interventional Radiology. 1991;2:485-488. UI 1832232. [pmid: 1839133].
Belli AM, Cumberland DC, Procter AE, Welsh CL. Total peripheral artery occlusions: conventional versus laser thermal recanalization with a hybrid probe in percutaneous angioplasty--results of a randomized trial. Radiology. 1991;181:57-60. UI 1839133. [pmid: 1832232].
Bergan JJ, Wilson SE, Wolf G, Deupree RH. Unexpected, late cardiovascular effects of surgery for peripheral artery disease. Veterans Affairs Cooperative Study 199. Archives of Surgery. 1123;127:1119-1123. UI 1387528. [pmid: 1387528].
Beyer-Enke SA, Soldner J, Zeitler E. Immediate sealing of arterial puncture site following femoropopliteal angioplasty: a prospective randomized trial. Cardiovascular & Interventional Radiology. 1996;19:406-410. UI 8994706. [pmid: 8994706].
Bonvini R, Baumgartner I, Do DD, Alerci M, Segatto JM, Tutta P, et al. Late acute thrombotic occlusion after endovascular brachytherapy and stenting of femoropopliteal arteries. Journal of the American College of Cardiology. 2003;41:409-412. UI 12575967. [pmid: 12575967].
Bosch JL, van der GY, Hunink MG. Health-related quality of life after angioplasty and stent placement in patients with iliac artery occlusive disease: results of a randomized controlled clinical trial. The Dutch Iliac Stent Trial Study Group. Circulation. 1999;99:3155-3160. UI 10377079. [pmid: 10377079].
Cejna M, Thurnher S, Illiasch H, Horvath W, Waldenberger P, Hornik K, et al. PTA versus Palmaz stent placement in femoropopliteal artery obstructions: a multicenter prospective randomized study. Journal of Vascular & Interventional Radiology. 2001;12:23-31. UI 11200349. [pmid: 11200349].
Creasy TS, McMillan PJ, Fletcher EW, Collin J, Morris PJ. Is percutaneous transluminal angioplasty better than exercise for claudication? Preliminary results from a prospective randomised trial. European Journal of Vascular Surgery. 1990;4:135-140. UI 2140987. [pmid: 2140987].
Diehm N, Silvestro A, Do DD, Greiner R, Triller J, Mahler F, et al. Endovascular brachytherapy after femoropopliteal balloon angioplasty fails to show robust clinical benefit over time. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2005;12:723-730. UI 16363902.
Fisher CM, Fletcher JP, May J, White GH, Lord RS, Crozier J, et al. No additional benefit from laser in balloon angioplasty of the superficial femoral artery. European Journal of Vascular & Endovascular Surgery. 1996;11:349-352. UI 8601248. [pmid: 8601248].
Fritz P, Stein U, Hasslacher C, Zierhut D, Wannenmacher M, Pritsch M. External beam radiotherapy fails to prevent restenosis after iliac or femoropopliteal percutaneous transluminal angioplasty: results of a prospective randomized double-blind study. International Journal of Radiation Oncology, Biology, Physics. 2004;59:815-821. UI 15183485.
Gallino A, Do DD, Alerci M, Baumgartner I, Cozzi L, Segatto JM, et al. Effects of probucol versus aspirin and versus brachytherapy on restenosis after femoropopliteal angioplasty: the PAB randomized multicenter trial. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2004;11:595-604. UI 15615549.
Gordon IL, Conroy RM, Tobis JM, Kohl C, Wilson SE. Determinants of patency after percutaneous angioplasty and atherectomy of occluded superficial femoral arteries. American Journal of Surgery. 1994;168:115-119. UI 8053507. [pmid: 8053507].
Greenberg D, Rosenfield K, Garcia LA, Berezin RH, Lavelle T, Fogleman S, et al. In-hospital costs of self-expanding nitinol stent implantation versus balloon angioplasty in the femoropopliteal artery (the VascuCoil Trial). Journal of Vascular & Interventional Radiology. 2004;15:1065-1069. UI 15466792. [pmid: 15466792].
Grenadier L, Saam T, Geier A, Muller-Hulsbeck S, Cejna M, Kauffmann GW, et al. [PTA versus Palmaz stent placement in femoropopliteal artery stenoses: results of a multicenter prospective randomized study (REFSA)]. [German]. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2004;176:1302-1310. UI 15346266. [pmid: 15346266].
Grimm J, Muller-Hulsbeck S, Jahnke T, Hilbert C, Brossmann J, Heller M. Randomized study to compare PTA alone versus PTA with Palmaz stent placement for femoropopliteal lesions. Journal of Vascular & Interventional Radiology. 2001;12:935-942. UI 11487673. [pmid: 11487673].
Heinz M, Theiss W, van de FE, Sohngen M. [The effect of Taprostene on platelet activation and clinical course after percutaneous transluminal angioplasty] [German]. Vasa. 1996;25:65-72. UI 8851268. [pmid: 8851268].
Hobbs SD, Marshall T, Fegan C, Adam DJ, Bradbury AW. The constitutive procoagulant and hypofibrinolytic state in patients with intermittent claudication due to infrainguinal disease significantly improves with percutaneous transluminal balloon angioplasty. Journal of Vascular Surgery. 2006;43:40-46. UI 16414385. [pmid: 16414385].
Jeans WD, Murphy P, Hughes AO, Horrocks M, Baird RN. Randomized trial of laser-assisted passage through occluded femoro-popliteal arteries. British Journal of Radiology. 1990;63:19-21. UI 2137717. [pmid: 2137717].
Kauffmann GW, Richter GM, Noldge G, Roeren T, Landwehr P, Lackner K. [4 years' experience with a balloon-expandable endoprosthesis. Experimental and clinical application]. [German]. Radiologe. 1991;31:202-209. UI 1829841. [pmid: 1829841].
Kedora J, Hohmann S, Garrett W, Munschaur C, Theune B, Gable D. Randomized comparison of percutaneous Viabahn stent grafts vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral arterial occlusive disease. Journal of Vascular Surgery. 1916;45:10-16. UI 17126520. [pmid: 17126520].
Klein WM, van der GY, Seegers J, Moll FL, Mali WP. Long-term cardiovascular morbidity, mortality, and reintervention after endovascular treatment in patients with iliac artery disease: The Dutch Iliac Stent Trial Study. Radiology. 2004;232:491-498. UI 15286319. [pmid: 15286319].
Klein WM, van der GY, Seegers J, Spithoven JH, Buskens E, van Baal JG, et al. Dutch iliac stent trial: long-term results in patients randomized for primary or selective stent placement. Radiology. 2006;238:734-744. UI 16371580. [pmid: 16371580].
Koppensteiner R, Spring S, mann-Vesti BR, Meier T, Pfammatter T, Rousson V, et al. Low-molecular-weight heparin for prevention of restenosis after femoropopliteal percutaneous transluminal angioplasty: a randomized controlled trial. Journal of Vascular Surgery. 2006;44:1247-1253. UI 17145426. [pmid: 17145426].
Krajcer Z, Sioco G, Reynolds T. Comparison of Wallgraft and Wallstent for treatment of complex iliac artery stenosis and occlusion. Preliminary results of a prospective randomized study. Texas Heart Institute Journal. 1997;24:193-199. UI 9339507. [pmid: 9339507].
Krueger K, Landwehr P, Bendel M, Nolte M, Stuetzer H, Bongartz R, et al. Endovascular gamma irradiation of femoropopliteal de novo stenoses immediately after PTA: interim results of prospective randomized controlled trial. Radiology. 2002;224:519-528. UI 12147851. [pmid: 12147851].
Krueger K, Zaehringer M, Bendel M, Stuetzer H, Strohe D, Nolte M, et al. De novo femoropopliteal stenoses: endovascular gamma irradiation following angioplasty--angiographic and clinical follow-up in a prospective randomized controlled trial. Radiology. 2004;231:546-554. UI 15064389. [pmid: 15064389].
Lammer J, Pilger E, Decrinis M, Quehenberger F, Klein GE, Stark G. Pulsed excimer laser versus continuous-wave Nd:YAG laser versus conventional angioplasty of peripheral arterial occlusions: prospective, controlled, randomised trial. Lancet. 1992;340:1183-1188. UI 1359260. [pmid: 1359260].
Meyerovitz MF, Didier D, Vogel JJ, Soulier-Parmeggiani L, Bounameaux H. Thrombolytic therapy compared with mechanical recanalization in non-acute peripheral arterial occlusions: a randomized trial. Journal of Vascular & Interventional Radiology. 1995;6:775-781. UI 8541683. [pmid: 8541683].
Minar E, Ahmadi A, Koppensteiner R, Maca T, Stumpflen A, Ugurluoglu A, et al. Comparison of effects of high-dose and low-dose aspirin on restenosis after femoropopliteal percutaneous transluminal angioplasty. Circulation. 1995;91:2167-2173. UI 7697845. [pmid: 7697845].
Minar E, Pokrajac B, Maca T, Ahmadi R, Fellner C, Mittlbock M, et al. Endovascular brachytherapy for prophylaxis of restenosis after femoropopliteal angioplasty : results of a prospective randomized study. Circulation. 2000;102:2694-2699. UI 11094034. [pmid: 11094034].
Nakamura S, Conroy RM, Gordon IL, Deutsch LS, Maheswaran B, Antone CS, et al. A randomized trial of transcutaneous extraction atherectomy in femoral arteries: intravascular ultrasound observations. Journal of Clinical Ultrasound. 1995;23:461-471. UI 7499516. [pmid: 7499516].
Nehler MR, Brass EP, Anthony R, Dormandy J, Jiao J, McNamara TO, et al. Adjunctive parenteral therapy with lipo-ecraprost, a prostaglandin El analog, in patients with critical limb ischemia undergoing distal revascularization does not improve 6-month outcomes. Journal of Vascular Surgery. 960(45):953-960. UI 17350216.
Nicholson T. Percutaneous transluminal angioplasty and enclosed thrombolysis versus percutaneous transluminal angioplasty in the treatment of femoropopliteal occlusions: results of a prospective randomized trial. Cardiovascular & Interventional Radiology. 1998;21:470-474. UI 9853164. [pmid: 9853164].
Nylaende M, Abdelnoor M, Stranden E, Morken B, Sandbaek G, Risum O, et al. The Oslo balloon angioplasty versus conservative treatment study (OBACT)--the 2-years results of a single centre, prospective, randomised study in patients with intermittent claudication. European Journal of Vascular & Endovascular Surgery. 2007;33:3-12. UI 17055756. [pmid: 17055756].
Perkins JM, Collin J, Creasy TS, Fletcher EW, Morris PJ. Exercise training versus angioplasty for stable claudication. Long and medium term results of a prospective, randomised trial. European Journal of Vascular & Endovascular Surgery. 1996;11:409-413. UI 8846172. [pmid: 8846172].
Pokrajac B, Potter R, Maca T, Fellner C, Mittlbock M, Ahmadi R, et al. Intraarterial (192)Ir high-dose-rate brachytherapy for prophylaxis of restenosis after femoropopliteal percutaneous transluminal angioplasty: the prospective randomized Vienna-2-trial radiotherapy parameters and risk factors analysis. International Journal of Radiation Oncology, Biology, Physics. 2000;48:923-931. UI 11072147.
Pokrajac B, Potter R, Wolfram RM, Budinsky AC, Kirisits C, Lileg B, et al. Endovascular brachytherapy prevents restenosis after femoropopliteal angioplasty: results of the Vienna-3 randomised multicenter study. Radiotherapy & Oncology. 2005;74:3-9. UI 15683661. [pmid: 15683661].
Pokrajac B, Schmid R, Kirisits C, Mock U, Fellner C, Wambersie A, et al. Possible impact of iridium-192 source centering on restenosis rate after femoro-popliteal angioplasty and endovascular brachytherapy in Vienna-2 study. Radiotherapy & Oncology. 2002;63:97-102. UI 12065109. [pmid: 12065109].
Ponec D, Jaff MR, Swischuk J, Feiring A, Laird J, Mehra M, et al. The Nitinol SMART stent vs Wallstent for suboptimal iliac artery angioplasty: CRISP-US trial results. Journal of Vascular & Interventional Radiology. 2004;15:911-918. UI 15361558. [pmid: 15361558].
Rand T, Basile A, Cejna M, Fleischmann D, Funovics M, Gschwendtner M, et al. PTA versus carbofilm-coated stents in infrapopliteal arteries: pilot study. Cardiovascular & Interventional Radiology. 2006;29:29-38. UI 16252079. [pmid: 16252079].
Richter GM, Roeren T, Noeldge G, Landwehr P, Allenberg JR, Kauffmann GW, et al. [Initial long-term results of a randomized 5-year study: iliac stent implantation versus PTA]. [German]. Vasa-Supplementum. 1992;35:192-193. UI 1481044. [pmid: 1481044].
Saxon RR, Coffman JM, Gooding JM, Natuzzi E, Ponec DJ. Long-term results of ePTFE stent-graft versus angioplasty in the femoropopliteal artery: single center experience from a prospective, randomized trial. Journal of Vascular & Interventional Radiology. 2003;14:303-311. UI 12631634. [pmid: 12631634].
Schillinger M, Sabeti S, Dick P, Amighi J, Mlekusch W, Schlager O, et al. Sustained benefit at 2 years of primary femoropopliteal stenting compared with balloon angioplasty with optional stenting. Circulation. 2007;115:2745-2749. UI 17502568. [pmid: 17502568].
Schillinger M, Sabeti S, Loewe C, Dick P, Amighi J, Mlekusch W, et al. Balloon angioplasty versus implantation of nitinol stents in the superficial femoral artery. New England Journal of Medicine. 2006;354:1879-1888. UI 16672699. [pmid: 16672699].
Spies JB, LeQuire MH, Brantley SD, Williams JE, Beckett WC, Mills JL. Comparison of balloon angioplasty and laser thermal angioplasty in the treatment of femoropopliteal atherosclerotic disease: initial results of a prospective randomized trial. Work in progress. Journal of Vascular & Interventional Radiology. 1990;1:39-42. UI 2151970. [pmid: 2151970].
Tetteroo E, Haaring C, van der GY, van Schaik JP, van Engelen AD, Mali WP. Intraarterial pressure gradients after randomized angioplasty or stenting of iliac artery lesions. Dutch Iliac Stent Trial Study Group. Cardiovascular & Interventional Radiology. 1996;19:411-417. UI 8994707. [pmid: 8994707].
Tetteroo E, van der GY, Bosch JL, van Engelen AD, Hunink MG, Eikelboom BC, et al. Randomised comparison of primary stent placement versus primary angioplasty followed by selective stent placement in patients with iliac-artery occlusive disease. Dutch Iliac Stent Trial Study Group. Lancet. 1998;351:1153-1159. UI 9643685. [pmid: 9643685].
Therasse E, Donath D, Lesperance J, Tardif JC, Guertin MC, Oliva VL, et al. External beam radiation to prevent restenosis after superficial femoral artery balloon angioplasty. Circulation. 2005;111:3310-3315. UI 15956130. [pmid: 15956130].
Tielbeek AV, Vroegindeweij D, Buth J, Landman GH. Comparison of balloon angioplasty and Simpson atherectomy for lesions in the femoropopliteal artery: angiographic and clinical results of a prospective randomized trial. Journal of Vascular & Interventional Radiology. 1996;7:837-844. UI 8951750. [pmid: 8951750].
Tobis JM, Conroy R, Deutsch LS, Gordon I, Honye J, Andrews J, et al. Laser-assisted versus mechanical recanalization of femoral arterial occlusions. American Journal of Cardiology. 1991;68:1079-1086. UI 1833969. [pmid: 1833969].
van der Zaag ES, Legemate DA, Prins MH, Reekers JA, Jacobs MJ. Angioplasty or bypass for superficial femoral artery disease? A randomised controlled trial. European Journal of Vascular & Endovascular Surgery. 2004;28:132-137. UI 15234692. [pmid: 15234692].
van der Zaag ES, Prins MH, Jacobs MJ. [Treatment of intermittent claudication; prospective randomized study in the BAESIC-Trial (bypass, angioplasty or endarterectomy patients with severe intermittent claudication)]. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1996;140:787-788. UI 8668267. [pmid: 8668267].
van Tongeren RB, van Sambeek MR, van OH, Coen VL, Schmitz PI, Gescher FM, et al. Endovascular brachytherapy for the prevention of restenosis after femoropopliteal angioplasty. Results of the VARA Trial. Journal of Cardiovascular Surgery. 2005;46:437-443. UI 16160691. [pmid: 16160691].
Vroegindeweij D, Kemper FJ, Tielbeek AV, Buth J, Landman G. Recurrence of stenoses following balloon angioplasty and Simpson atherectomy of the femoro-popliteal segment. A randomised comparative 1-year follow-up study using colour flow duplex. European Journal of Vascular Surgery. 1992;6:164-171. UI 1533372. [pmid: 1533372].
Vroegindeweij D, Tielbeek AV, Buth J, Schol FP, Hop WC, Landman GH. Directional atherectomy versus balloon angioplasty in segmental femoropopliteal artery disease: two-year follow-up with color-flow duplex scanning. Journal of Vascular Surgery. 268(21):255-268. UI 7853599.
Vroegindeweij D, Vos LD, Tielbeek AV, Buth J, vd Bosch HC. Balloon angioplasty combined with primary stenting versus balloon angioplasty alone in femoropopliteal obstructions: A comparative randomized study. Cardiovascular & Interventional Radiology. 1997;20:420-425. UI 9354709. [pmid: 9354709].
Whyman MR, Fowkes FG, Kerracher EM, Gillespie IN, Lee AJ, Housley E, et al. Randomised controlled trial of percutaneous transluminal angioplasty for intermittent claudication. European Journal of Vascular & Endovascular Surgery. 1996;12:167-172. UI 9357454. [pmid: 8760978].
Whyman MR, Fowkes FG, Kerracher EM, Gillespie IN, Lee AJ, Housley E, et al. Is intermittent claudication improved by percutaneous transluminal angioplasty? A randomized controlled trial. Journal of Vascular Surgery. 1997;26:551-557. UI 8760978. [pmid: 9357454].
Wilson SE, Wolf GL, Cross AP. Percutaneous transluminal angioplasty versus operation for peripheral arteriosclerosis. Report of a prospective randomized trial in a selected group of patients. Journal of Vascular Surgery. 1989;9(1):9. UI 2521362.
Wolfram RM, Budinsky AC, Pokrajac B, Potter R, Minar E. Endovascular brachytherapy: restenosis in de novo versus recurrent lesions of femoropopliteal artery--the Vienna experience.[erratum appears in Radiology. 2006 May; 239(2):613]. Radiology. 2005;236:338-342. UI 16926331. [pmid: 15955854].
Wolfram RM, Budinsky AC, Pokrajac B, Potter R, Minar E. Endovascular brachytherapy for prophylaxis of restenosis after femoropopliteal angioplasty: five-year follow-up--prospective randomized study. Radiology. 2006;240:878-884. UI 15955854. [pmid: 16926331].
Wyttenbach R, Gallino A, Alerci M, Mahler F, Cozzi L, Di VM, et al. Effects of percutaneous transluminal angioplasty and endovascular brachytherapy on vascular remodeling of human femoropopliteal artery by noninvasive magnetic resonance imaging. Circulation. 2004;110:1156-1161. UI 15326071. [pmid: 15326071].
Zdanowski Z, Albrechtsson U, Lundin A, Jonung T, Ribbe E, Thorne J, et al. Percutaneous transluminal angioplasty with or without stenting for femoropopliteal occlusions? A randomized controlled study. International Angiology. 1999;18:251-255. UI 10811511. [pmid: 10811511].
Zehnder T, von BC, Baumgartner I, Triller J, Greiner R, Mahler F, et al. Endovascular brachytherapy after percutaneous transluminal angioplasty of recurrent femoropopliteal obstructions. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2003;10:304-311. UI 12877614.
Zorger N, Manke C, Lenhart M, Finkenzeller T, Djavidani B, Feuerbach S, et al. Peripheral arterial balloon angioplasty: effect of short versus long balloon inflation times on the morphologic results. Journal of Vascular & Interventional Radiology. 2002;13:355-359. UI 11932365. [pmid: 11932365].

## Nonrandomized comparative studies that evaluate PTA

Al-Omran M, Tu JV, Johnston KW, Mamdani MM, Kucey DS. Outcome of revascularization procedures for peripheral arterial occlusive disease in Ontario between 1991 and 1998: a population-based study. Journal of Vascular Surgery. 2003;38:279-288. UI 9257667. [pmid: 12891109].
Alimi Y, Di MP, Barthelemy P, Juhan C. Iliac transluminal angioplasty and distal surgical revascularisation can be performed in a one-step technique. International Angiology. 1997;16:83-87. UI 12891109. [pmid: 9257667].
Aschauer M, Hausegger KA, Lammer J, Klein GE, Fluckiger F, Lafer M, et al. [Percutaneous recanalization of iliac artery occlusions--retrospective analysis before and following availability of stents].[German]. Vasa - Supplementum. 1991;33:197-198. UI 1838635. [pmid: 1838635].
Becquemin JP, Allaire E, Qvarfordt P, Desgranges P, Kobeiter H, Melliere D. Surgical transluminal iliac angioplasty with selective stenting: long-term results assessed by means of duplex scanning. Journal of Vascular Surgery. 1999;29:422-429. UI 10069906. [pmid: 10069906].
Becquemin JP, Cavillon A, Allaire E, Haiduc F, Desgranges P. Iliac and femoropopliteal lesions: evaluation of balloon angioplasty and classical surgery. Journal of Endovascular Surgery. 1995;2:42-50. UI 9234117. [pmid: 9234117].
Benhamou AC, Acquaviva P, Zerez A, Castellani L, Alison D. [Peroperative endoluminal dilatation or recanalization (DELPO or RCPO) in arteriopathies of the lower extremities. A new therapeutic weapon for the vascular surgeon. Apropos of 42 cases]. [French]. Journal des Maladies Vasculaires. 1986;11:379-387. UI 2949036. [pmid: 2949036].
Blair JM, Gewertz BL, Moosa H, Lu CT, Zarins CK. Percutaneous transluminal angioplasty versus surgery for limb-threatening ischemia. Journal of Vascular Surgery. 1989;9:698-703. UI 2524606. [pmid: 2524606].
Bongard O, Didier D, Bounameaux H. Effects of percutaneous transluminal angioplasty on skin microcirculation in patients with disabling peripheral arterial occlusive disease. International Journal of Microcirculation: Clinical & Experimental. 1994;14:319-326. UI 7635647.
Bosch JL, Haaring C, Meyerovitz MF, Cullen KA, Hunink MG. Cost-effectiveness of percutaneous treatment of iliac artery occlusive disease in the United States. AJR. 2000;American:517-521. UI 10915706. [pmid: 10915706].
Bosch JL, Tetteroo E, Mali WP, Hunink MG. Iliac arterial occlusive disease: cost-effectiveness analysis of stent placement versus percutaneous transluminal angioplasty. Dutch Iliac Stent Trial Study Group. Radiology. 1998;208:641-648. UI 9722840. [pmid: 9722840].
Bosiers M, Hart JP, Deloose K, Verbist J, Peeters P. Endovascular therapy as the primary approach for limb salvage in patients with critical limb ischemia: experience with 443 infrapopliteal procedures. Vascular. 2006;14:63-69. UI 16956473. [pmid: 16956473].
Brenot P, Raynaud A, Pernes JM, Parola JL, Gaux JC. [Comparative study of the carrying out of iliac angioplasty with digital and conventional angiography. Impact on real (consumable) costs]. [French]. Journal de Radiologie. 1986;67:643-646. UI 2948013. [pmid: 2948013].
Burkle G, Burkle H. [The place of local, low-dose, short-duration fibrinolysis in the management concept of arterial occlusive diseases]. [German]. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 1991;155:393-404. UI 1835409. [pmid: 1835409].
Cambria RA, Farooq MM, Mewissen MW, Freischlag JA, Seabrook GR, Crain MR, et al. Endovascular therapy of iliac arteries: routine application of intraluminal stents does not improve clinical patency. Annals of Vascular Surgery. 1999;13:599-605. UI 10541614. [pmid: 10541614].
Cejna M, Schoder M, Lammer J. [PTA vs. stent in femoro-popliteal obstruction]. [German]. Radiologe. 1999;39:144-150. UI 10093840. [pmid: 10093840].
Chiesa R, Castrucci M, Spiegel P, Melissano G, Venturini M, Esposito G, et al. [Treatment of obliterating arteriopathies of the lower limbs using angioplasty. Comparison of 2 techniques of recanalization: Nd-YAG laser and radiofrequency thermal probe]. [Italian]. Minerva Chirurgica. 1990;45:1303-1307. UI 2150542. [pmid: 2150542].
Cho L, Roffi M, Mukherjee D, Bhatt DL, Bajzer C, Yadav JS. Superficial femoral artery occlusion: nitinol stents achieve better flow and reduce the need for medications than balloon angioplasty alone. Journal of Invasive Cardiology. 2003;15:198-200. UI 12668846. [pmid: 12668846].
Cole SE, Baird RN, Horrocks M, Jeans WD. The role of balloon angioplasty in the management of lower limb ischaemia. European Journal of Vascular Surgery. 1987;1:61-65. UI 2972562. [pmid: 2972562].
Costanza MJ, Queral LA, Lilly MP, Finn WR. Hemodynamic outcome of endovascular therapy for TransAtlantic InterSociety Consensus type B femoropopliteal arterial occlusive lesions. Journal of Vascular Surgery. 2004;39:343-350. UI 14743134. [pmid: 14743134].
Courchia G, Serise JM, Moreau JL, Delorge C, Winnock S, Boissieras P. [Peroperative angiography in reparative surgery of the lower limbs. Apropos of experience with 1099 cases]. [French]. Journal des Maladies Vasculaires. 1988;13:11-19. UI 2964494. [pmid: 2964494].
Crew JR, Thuener M. Wound Healing: An endpoint for complex peripheral angioplasty. Journal of Endovascular Surgery. 1994;1:88-91. UI 9234109. [pmid: 9234109].
Cull DL, Feinberg RL, Wheeler JR, Snyder SO Jr, Gregory RT, Gayle RG, et al. Experience with laser-assisted balloon angioplasty and a rotary angioplasty instrument: lessons learned. Journal of Vascular Surgery. 1991;14:332-339. UI 1831862. [pmid: 1831862].
Currie IC, Wilson YG, Baird RN, Lamont PM. Treatment of intermittent claudication: the impact on quality of life. European Journal of Vascular & Endovascular Surgery. 1995;10:356-361. UI 7552539. [pmid: 7552539].
d'Othee BJ, Haulon S, Mounier-Vehier C, Beregi JP, Jabourek O, Willoteaux S. Percutaneous endovascular treatment for stenoses and occlusions of infrarenal aorta and aortoiliac bifurcation: midterm results. European Journal of Vascular & Endovascular Surgery. 2002;24:516-523. UI 1833845. [pmid: 12443747].
d'Othee BJ, Langdon DR, Bell GK, Bettmann MA. Operating expenses for the diagnosis and treatment of peripheral vascular disease in an academic interventional radiology department: cost calculations according to a microeconomic method. Journal of Vascular & Interventional Radiology. 2006;17:85-94. UI 11756701. [pmid: 16415137].
Dalsing MC, Cockerill E, Deupree R, Wolf G, Wilson S. Outcome predictors in selection of balloon angioplasty or surgery for peripheral arterial occlusive disease. Veterans Administration Cooperative Study No. 199. Surgery. 643(110):636-643. UI 17306950.
de Vries SO, Visser K, de Vries JA, Wong JB, Donaldson MC, Hunink MG. Intermittent claudication: cost-effectiveness of revascularization versus exercise therapy. Radiology. 2002;222:25-36. UI 7972781. [pmid: 11756701].
Dick F, Diehm N, Galimanis A, Husmann M, Schmidli J, Baumgartner I. Surgical or endovascular revascularization in patients with critical limb ischemia: influence of diabetes mellitus on clinical outcome. Journal of Vascular Surgery. 2007;45:751-761. UI 1423391. [pmid: 17306950].
Do DD, Mahler F. Low-dose aspirin combined with dipyridamole versus anticoagulants after femoropopliteal percutaneous transluminal angioplasty. Radiology. 1994;193:567-571. UI 17071186. [pmid: 7972781].
Do dD, Triller J, Walpoth BH, Stirnemann P, Mahler F. A comparison study of self-expandable stents vs balloon angioplasty alone in femoropopliteal artery occlusions. Cardiovascular & Interventional Radiology. 1992;15:306-312. UI 12443747. [pmid: 1423391].
Dosluoglu HH, O'Brien-Irr MS, Lukan J, Harris LM, Dryjski ML, Cherr GS. Does preferential use of endovascular interventions by vascular surgeons improve limb salvage, control of symptoms, and survival of patients with critical limb ischemia?. American Journal of Surgery. 2006;192:572-576. UI 16415137. [pmid: 17071186].
Faglia E, Clerici G, Clerissi J, Gabrielli L, Losa S, Mantero M, et al. Early and five-year amputation and survival rate of diabetic patients with critical limb ischemia: data of a cohort study of 564 patients. European Journal of Vascular & Endovascular Surgery. 2006;32:484-490. UI 16730466. [pmid: 16730466].
Feinglass J, McCarthy WJ, Slavensky R, Manheim LM, Martin GJ. Functional status and walking ability after lower extremity bypass grafting or angioplasty for intermittent claudication: results from a prospective outcomes study. Journal of Vascular Surgery. 2000;31:t-103. UI 10642712.
Fichelle JM, Marzelle J, Colacchio G, Gigou F, Cormier F, Cormier JM. Infrapopliteal polytetrafluoroethylene and composite bypass: factors influencing patency. Annals of Vascular Surgery. 1995;9:187-196. UI 7786705. [pmid: 7786705].
Gehani AA, Thorley P, Sheard K, Ashley S, Brook SG, Rees MR. Value of a radionuclide limb blood flow technique in the assessment of percutaneous balloon and dynamic angioplasty. European Journal of Nuclear Medicine. 1992;19:6-13. UI 1532146. [pmid: 1532146].
Gschwandtner ME, Minar E, Ahmadi A, Haumer M, Hulsmann M, Maca T, et al. Impact of different therapeutic alternatives in treatment of severe limb ischemia: experiences on 190 consecutive patients at a department of medical angiology. Vasa. 1999;28:271-278. UI 10611845. [pmid: 10611845].
Hassen-Khodja R, Sala F, Declemy S, Bouillanne PJ, Batt M, Staccini P. Value of stent placement during percutaneous transluminal angioplasty of the iliac arteries. Journal of Cardiovascular Surgery. 2001;42:369-374. UI 11398035. [pmid: 11398035].
Hsiang YN, al-Salman M, Doyle DL, Machan LS. Comparison of percutaneous with intra-operative balloon angioplasty for arteriosclerotic occlusive disease. Australian & New Zealand Journal of Surgery. 1993;63:864-569. UI 8216064. [pmid: 8216064].
Hunink MG, Cullen KA, Donaldson MC. Hospital costs of revascularization procedures for femoropopliteal arterial disease. Journal of Vascular Surgery. 1994;19:632-641. UI 8164278. [pmid: 8164278].
Huppert PE, Duda SH, Helber U, Karsch KR, Claussen CD. Comparison of pulsed laser-assisted angioplasty and balloon angioplasty in femoropopliteal artery occlusions. Radiology. 1992;184:363-367. UI 1535716. [pmid: 1535716].
Huppert PE, Seboldt H, Duda SH, Seiter H, Claussen CD, Hoffmeister HE. Laser angioplasty of peripheral arterial occlusive disease. Thoracic & Cardiovascular Surgeon. 1991;39. Suppl-51. UI 1839476.
Iida O, Nanto S, Uematsu M, Morozumi T, Kotani J, Awata M, et al. Cilostazol reduces target lesion revascularization after percutaneous transluminal angioplasty in the femoropopliteal artery. Circulation Journal. 2005;69:1256-1259. UI 16195627. [pmid: 16195627].
Kalbaugh CA, Taylor SM, Blackhurst DW, Dellinger MB, Trent EA, Youkey JR. One-year prospective quality-of-life outcomes in patients treated with angioplasty for symptomatic peripheral arterial disease. Journal of Vascular Surgery. 302(44):296-302. UI 16814976.
Karanjia ND, Loosemore TM, Ray SA, Buckenham TM, Taylor RS, Dormandy JA. The differences in early haemodynamic response between surgery and angioplasty after successful reopening of the superficial femoral artery. European Journal of Vascular Surgery. 1993;7:717-719. UI 8270078. [pmid: 8270078].
Klevsgard R, Hallberg IR, Risberg B, Thomsen MB. The effects of successful intervention on quality of life in patients with varying degrees of lower-limb ischaemia. European Journal of Vascular & Endovascular Surgery. 2000;19:238-245. UI 10753686. [pmid: 10753686].
Kodera K, Ishitobi K, Hiramatsu K. [Percutaneous transluminal angioplasty of iliac and femoral artery stenoses. On the difference of the initial success rate by the approach methods]. [Japanese]. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica. 1985;45:1309-1312. UI 2935783.
Kotb MM, Kadir S, Bennett JD, Beam CA. Aortoiliac angioplasty: is there a need for other types of percutaneous intervention?. Journal of Vascular & Interventional Radiology. 1992;3:67-71. UI 1531773. [pmid: 1531773].
Kudo T, Chandra FA, Ahn SS. Long-term outcomes and predictors of iliac angioplasty with selective stenting. Journal of Vascular Surgery. 2005;42:466-475. UI 16171589. [pmid: 16171589].
Kwasnik EM, Siouffi SY, Jay ME, Khuri SF. Comparative results of angioplasty and aortofemoral bypass in patients with symptomatic iliac disease. Archives of Surgery. 1987;122:288-291. UI 2950842. [pmid: 2950842].
Lammer J, Karnel F. Percutaneous transluminal laser angioplasty with contact probes. Radiology. 1988;168:733-737. UI 2970099. [pmid: 2970099].
Laxdal E, Wirsching J, Jenssen GL, Pedersen G, Aune S, Daryapeyma A. Endovascular treatment of isolated atherosclerotic lesions of the infrarenal aorta is technically feasible with acceptable long-term results. European Journal of Radiology. 2007;61:541-544. UI 17258418. [pmid: 17258418].
Luft C, Horvath W, Oertl M, Haidinger D. [Laser versus rotation angioplasty in the recanalization of chronic femoropopliteal arterial occlusions]. [German]. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 1993;158:53-58. UI 8425077. [pmid: 8425077].
Martin EC, Fankuchen El, Karlson KB, Dolgin C, Collins RH, Voorhees AB Jr, et al. Angioplasty for femoral artery occlusion: comparison with surgery. AJR. 1981;American:915-919. UI 6457522. [pmid: 6457522].
Maspes F, Innocenzi L, Ascoli MA, Cossu E, Squillaci E, Pistolese GR, et al. [Percutaneous transluminal angioplasty in the treatment of iliac stenosis. The authors' new guideline for 100 patients]. [Italian]. Radiologia Medica. 1995;90:772-780. UI 8685462. [pmid: 8685462].
Mohr R, Smolinsky A, Morag B, Bass A, Rubinstein ZJ, Adar R. Cardiac complications in vascular procedures: comparison of percutaneous angioplasty and surgery. Catheterization & Cardiovascular Diagnosis. 1983;9:339-343. UI 6226360. [pmid: 6226360].
Odink HF, de Valois HC, Eikelboom BC. Femoropopliteal arterial occlusions: laser-assisted versus conventional percutaneous transluminal angioplasty. Radiology. 1991;181:61-66. UI 7648592. [pmid: 1832233].
Odink HF, de Valois HC, Eikelboom BC. Femoropopliteal artery recanalization: factors affecting clinical outcome of conventional and laser-assisted balloon angioplasty. Cardiovascular & Interventional Radiology. 1995;18:162-167. UI 1832233. [pmid: 7648592].
Parmar JH, Aslam M, Standfield NJ. Peripheral arterial revascularization causing parallel increased activity of pro- and anti-inflammatory mediators. International Angiology. 2007;26:8-11. UI 17353882. [pmid: 17353882].
Pell JP, Lee AJ. Impact of angioplasty and arterial reconstructive surgery on the quality of life of claudicants. The Scottish Vascular Audit Group. Scottish Medical Journal. 1997;42:47-48. UI 9507581. [pmid: 9507581].
Pilger E, Decrinis M, Stark G, Koch G, Obernosterer A, Tischler R, et al. Thrombolytic treatment and balloon angioplasty in chronic occlusion of the aortic bifurcation. Annals of Internal Medicine. 1994;120:40-44. UI 8250455. [pmid: 8250455].
Pozzi MF, Fisicaro M, Calderan L, Malacrea M, Mazzone C, Cattin L, et al. Percutaneous revascularization of femoropopliteal artery disease: PTA and PTA plus stent. Results after six years' follow-up. Radiologia Medica. 2003;105:339-349. UI 12835627. [pmid: 12835627].
Rendl KH, Prenner K. [3 years' experience with intraoperative transluminal angioplasty--a retrospective study]. [German]. Langenbecks Archiv fur Chirurgie. 1983;360:295-301. UI 6229677. [pmid: 6229677].
Sapienza P, Mingoli A, McGill JE, Perdikis G, Cavallari N, Feldhaus RJ. Comparative long-term results of laser-assisted balloon angioplasty and atherectomy in the treatment of peripheral vascular disease. American Journal of Surgery. 644(168):640-644. UI 7978011.
Schillinger M, Exner M, Mlekusch W, Haumer M, Ahmadi R, Rumpold H, et al. Balloon angioplasty and stent implantation induce a vascular inflammatory reaction. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2002;9:59-66. UI 11958327.
Schillinger M, Exner M, Mlekusch W, Rumpold H, Ahmadi R, Sabeti S, et al. Fibrinogen predicts restenosis after endovascular treatment of the iliac arteries. Thrombosis & Haemostasis. 2002;87:959-965. UI 12083502. [pmid: 12083502].
Schillinger M, Mlekusch W, Haumer M, Sabeti S, Ahmadi R, Minar E. Angioplasty and elective stenting of de novo versus recurrent femoropopliteal lesions: 1-year follow-up. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2003;10:288-297. UI 12877612.
Schlager O, Dick P, Sabeti S, Amighi J, Mlekusch W, Minar E, et al. Long-segment SFA stenting--the dark sides: in-stent restenosis, clinical deterioration, and stent fractures. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2005;12:676-684. UI 16363897.
Schneider PA, Abcarian PW, Ogawa DY, Leduc JR, Wright PW. Should balloon angioplasty and stents have any role in operative intervention for lower extremity ischemia?. Annals of Vascular Surgery. 1997;11:574-580. UI 9363302. [pmid: 9363302].
Schneider PA, Caps MT, Ogawa DY, Hayman ES. Intraoperative superficial femoral artery balloon angioplasty and popliteal to distal bypass graft: an option for combined open and endovascular treatment of diabetic gangrene. Journal of Vascular Surgery. 2001;33:955-962. UI 11331834. [pmid: 11331834].
Sciannameo F, Ronca P, Caselli M, Alberti D. [Surgery vs PTA in sub-inguinal atherosclerosis].[Italian]. Minerva Cardioangiologica. 1993;41:123-128. UI 8332267. [pmid: 8332267].
Siablis D, Karnabatidis D, Katsanos K, Kagadis GC, Kraniotis P, Diamantopoulos A, et al. Sirolimus-eluting versus bare stents after suboptimal infrapopliteal angioplasty for critical limb ischemia: enduring 1-year angiographic and clinical benefit. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2007;14:241-250. UI 17484536.
Simonetti G, Urigo F, Guazzaroni M, Biglioli P, Dettori G, Bacciu PP. Iliac artery lesions: a comparison between percutaneous transluminal angioplasty and surgery. Annales de Radiologie. 1986;29:127-129. UI 2943205. [pmid: 2943205].
Steckmeier B, Parzhuber A, Verrel F, Kellner W, Reininger C. [Simultaneous vascular and endovascular surgery of complex vascular diseases]. [German]. Langenbecks Archiv fur Chirurgie -Supplement - Kongressband. 1998;115:532-537. UI 9931673.
Steinkamp HJ, Rademaker J, Wissgott C, Scheinert D, Werk M, Settmacher U, et al. Percutaneous transluminal laser angioplasty versus balloon dilation for treatment of popliteal artery occlusions. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2002;9:882-888. UI 12546591.
Tato F, Hoffmann U, Weber C, Reiser M, Rieger J. Comparison of angiography, duplex sonography and intravascular ultrasound for the graduation of femoropopliteal stenoses before and after balloon angioplasty. Ultrasound in Medicine & Biology. 2006;32:1837-1843. UI 17169696. [pmid: 17169696].
Thalhammer A, Balzer J, Jacobi V, Vogl T. [Stents in the iliac arteries: a minimally invasive method]. [German]. Hamostaseologie. 2003;23:67-70. UI 12736701. [pmid: 12736701].
Therasse E, Cote G, Oliva VL, Cusson JR, Wistaff R, Nguyen PV, et al. Infrarenal aortic stenosis: value of stent placement after percutaneous transluminal angioplasty failure. Radiology. 2001;219:655-662. UI 11376250. [pmid: 11376250].
Thompson JF, McShane MD, Gazzard V, Clifford PC, Chant AD. Limitations of percutaneous transluminal angioplasty in the treatment of femoro-distal graft stenoses. European Journal of Vascular Surgery. 1989;3:209-211. UI 2526024. [pmid: 2526024].
Timaran CH, Ohki T, Gargiulo NJ III, Veith FJ, Stevens SL, Freeman MB, et al. Iliac artery stenting in patients with poor distal runoff: Influence of concomitant infrainguinal arterial reconstruction. Journal of Vascular Surgery. 484(38):479-484. UI 12947261.
Tonnesen KH, Bulow J, Holstein P, Helgstrand U. Comparison of efficacy in crossing femoropopliteal artery occlusions with movable core and hydrophilic guidewires. Cardiovascular & Interventional Radiology. 1994;17:319-322. UI 7882399. [pmid: 7882399].
Trocciola SM, Chaer R, Dayal R, Lin SC, Kumar N, Rhee J, et al. Comparison of results in endovascular interventions for infrainguinal lesions: claudication versus critical limb ischemia. American Surgeon. 479(71):474-479. UI 16044925.
Vogel TR, Su LT, Symons RG, Flum DR. Lower extremity angioplasty for claudication: a population-level analysis of 30-day outcomes. Journal of Vascular Surgery. 2007;45:762-767. UI 17303366. [pmid: 17303366].
Vogt KJ, Rasmussen JG, Just S, Schroeder TV. Effect and outcome of balloon angioplasty and stenting of the iliac arteries evaluated by intravascular ultrasound. European Journal of Vascular & Endovascular Surgery. 1999;17:47-55. UI 10071617. [pmid: 10071617].
Vroegindeweij D, Idu M, Buth J, Nillesen C, Schol FP, Tielbeek AV. The cost-effectiveness of treatment of short occlusive lesions in the femoropopliteal artery: balloon angioplasty versus endarterectomy. European Journal of Vascular & Endovascular Surgery. 1995;10:40-50. UI 7633969. [pmid: 7633969].
Westcott MA, Bonn J. Comparison of conventional angioplasty with the Palmaz stent in the treatment of abdominal aortic stenoses from the STAR registry. SCVIR Transluminal Angioplasty and Revascularization. Journal of Vascular & Interventional Radiology. 1998;9:225-231. UI 9540904. [pmid: 9540904].
Wilhelm C, Schomig A, Brachmann J, Amendt K, Sieben J, Weiss T, et al. [Comparison between argon and excimer laser angioplasty in patients with lesions of the femoral and popliteal arteries: clinical and angiography results after 1 year]. [German]. Vasa. 1993;22:169-177. UI 8322505. [pmid: 8322505].
Yilmaz S, Sindel T, Luleci E. Subintimal versus intraluminal recanalization of chronic iliac occlusions. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2004;11:107-118. UI 15056028.
Yoshitomi Y, Kojima S, Umemoto T, Hosoi Y, Kuramochi M. A retrospective study of late outcome in patients with peripheral arterial occlusive disease: an association between prosthetic vascular graft and cancer death?. Angiology. 1999;50:1007-1015. UI 10609767. [pmid: 10609767].
Zan S, Varetto G, Maselli M, Conforti M, Moniaci D, Scovazzi P. [Therapeutic approach to the unilateral occlusive iliac artery disease. Preliminary results]. [Italian]. Minerva Cardioangiologica. 2003;51:71-77. UI 12652263. [pmid: 12652263].

## Case control studies that evaluate PTA

Ahmadi R, Ugurluoglu A, Schillinger M, Katzenschlager R, Sabeti S, Minar E. Duplex ultrasound-guided femoropopliteal angioplasty: initial and 12-month results from a case controlled study. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2002;9:873-881. UI 12546590.
Al-Hamali S, Baskerville P, Fraser S, Walters H, Markus HS. Detection of distal emboli in patients with peripheral arterial stenosis before and after iliac angioplasty: a prospective study. Journal of Vascular Surgery. 1999;29:345-351. UI 9950992. [pmid: 9950992].
Hausegger KA, Lammer J, Klein GE, Fluckiger F, Lafer M, Pilger E, et al. [Percutaneous recanalization of pelvic artery occlusions�fibrinolysis, PTA, stents]. [German]. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 1991;155:550-555. UI 1837240. [pmid: 1837240].
Ohnishi K, Kato M, Ohtani M, Imagawa H, Takano H, Yoshioka Y. [Comparison of long-term patency rates of transluminal angioplasty and bypass grafting]. [Japanese]. Nippon Geka Gakkai Zasshi. 1992;Journal:1049-1051. UI 1470115. [pmid: 1470115].

## RCTs that evaluate stents

Ansel GM, Silver MJ, Botti CF Jr, Rocha-Singh K, Bates MC, Rosenfield K, et al. Functional and clinical outcomes of nitinol stenting with and without abciximab for complex superficial femoral artery disease: a randomized trial. Catheterization & Cardiovascular Interventions. 2006;67:288-297. UI 16408299. [pmid: 16408299].
Becquemin JP, Favre JP, Marzelle J, Nemoz C, Corsin C, Leizorovicz A. Systematic versus selective stent placement after superficial femoral artery balloon angioplasty: a multicenter prospective randomized study. Journal of Vascular Surgery. 2003;37:487-494. UI 12618680. [pmid: 12618680].
Bonvini R, Baumgartner I, Do DD, Alerci M, Segatto JM, Tutta P, et al. Late acute thrombotic occlusion after endovascular brachytherapy and stenting of femoropopliteal arteries. Journal of the American College of Cardiology. 2003;41:409-412. UI 12575967. [pmid: 12575967].
Bosch JL, van der GY, Hunink MG. Health-related quality of life after angioplasty and stent placement in patients with iliac artery occlusive disease: results of a randomized controlled clinical trial. The Dutch Iliac Stent Trial Study Group. Circulation. 1999;99:3155-3160. UI 10377079. [pmid: 10377079].
Cejna M, Thurnher S, Illiasch H, Horvath W, Waldenberger P, Hornik K, et al. PTA versus Palmaz stent placement in femoropopliteal artery obstructions: a multicenter prospective randomized study. Journal of Vascular & Interventional Radiology. 2001;12:23-31. UI 11200349. [pmid: 11200349].
Duda SH, Bosiers M, Lammer J, Scheinert D, Zeller T, Oliva V, et al. Drug-eluting and bare nitinol stents for the treatment of atherosclerotic lesions in the superficial femoral artery: long-term results from the SIROCCO trial. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2006;13:701-710. UI 17154704.
Duda SH, Bosiers M, Lammer J, Scheinert D, Zeller T, Tielbeek A, et al. Sirolimus-eluting versus bare nitinol stent for obstructive superficial femoral artery disease: the SIROCCO II trial. Journal of Vascular & Interventional Radiology. 2005;16:331-338. UI 15758128. [pmid: 15758128].
Duda SH, Pusich B, Richter G, Landwehr P, Oliva VL, Tielbeek A, et al. Sirolimus-eluting stents for the treatment of obstructive superficial femoral artery disease: six-month results. Circulation. 2002;106:1505-1509. UI 12234956. [pmid: 12234956].
Greenberg D, Rosenfield K, Garcia LA, Berezin RH, Lavelle T, Fogleman S, et al. In-hospital costs of self-expanding nitinol stent implantation versus balloon angioplasty in the femoropopliteal artery (the VascuCoil Trial). Journal of Vascular & Interventional Radiology. 2004;15:1065-1069. UI 15466792. [pmid: 15466792].
Grenadier L, Saam T, Geier A, Muller-Hulsbeck S, Cejna M, Kauffmann GW, et al. [PTA versus Palmaz stent placement in femoropopliteal artery stenoses: results of a multicenter prospective randomized study (REFSA)]. [German]. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2004;176:1302-1310. UI 15346266. [pmid: 15346266].
Grimm J, Muller-Hulsbeck S, Jahnke T, Hilbert C, Brossmann J, Heller M. Randomized study to compare PTA alone versus PTA with Palmaz stent placement for femoropopliteal lesions. Journal of Vascular & Interventional Radiology. 2001;12:935-942. UI 11487673. [pmid: 11487673].
Kauffmann GW, Richter GM, Noldge G, Roeren T, Landwehr P, Lackner K. [4 years' experience with a balloon-expandable endoprosthesis. Experimental and clinical application]. [German]. Radiologe. 1991;31:202-209. UI 1829841. [pmid: 1829841].
Kedora J, Hohmann S, Garrett W, Munschaur C, Theune B, Gable D. Randomized comparison of percutaneous Viabahn stent grafts vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral arterial occlusive disease. Journal of Vascular Surgery. 1916;45:10-16. UI 17126520. [pmid: 17126520].
Klein WM, van der GY, Seegers J, Moll FL, Mali WP. Long-term cardiovascular morbidity, mortality, and reintervention after endovascular treatment in patients with iliac artery disease: The Dutch Iliac Stent Trial Study. Radiology. 2004;232:491-498. UI 15286319. [pmid: 15286319].
Klein WM, van der GY, Seegers J, Spithoven JH, Buskens E, van Baal JG, et al. Dutch iliac stent trial: long-term results in patients randomized for primary or selective stent placement. Radiology. 2006;238:734-744. UI 16371580. [pmid: 16371580].
Krajcer Z, Sioco G, Reynolds T. Comparison of Wallgraft and Wallstent for treatment of complex iliac artery stenosis and occlusion. Preliminary results of a prospective randomized study. Texas Heart Institute Journal. 1997;24:193-199. UI 9339507. [pmid: 9339507].
Minar E, Pokrajac B, Maca T, Ahmadi R, Fellner C, Mittlbock M, et al. Endovascular brachytherapy for prophylaxis of restenosis after femoropopliteal angioplasty : results of a prospective randomized study. Circulation. 2000;102:2694-2699. UI 11094034. [pmid: 11094034].
Ponec D, Jaff MR, Swischuk J, Feiring A, Laird J, Mehra M, et al. The Nitinol SMART stent vs Wallstent for suboptimal iliac artery angioplasty: CRISP-US trial results. Journal of Vascular & Interventional Radiology. 2004;15:911-918. UI 15361558. [pmid: 15361558].
Rand T, Basile A, Cejna M, Fleischmann D, Funovics M, Gschwendtner M, et al. PTA versus carbofilm-coated stents in infrapopliteal arteries: pilot study. Cardiovascular & Interventional Radiology. 2006;29:29-38. UI 16252079. [pmid: 16252079].
Richter GM, Roeren T, Noeldge G, Landwehr P, Allenberg JR, Kauffmann GW, et al. [Initial long-term results of a randomized 5-year study: iliac stent implantation versus PTA]. [German]. Vasa - Supplementum. 1992;35:192-193. UI 1481044. [pmid: 1481044].
Saxon RR, Coffman JM, Gooding JM, Natuzzi E, Ponec DJ. Long-term results of ePTFE stent-graft versus angioplasty in the femoropopliteal artery: single center experience from a prospective, randomized trial. Journal of Vascular & Interventional Radiology. 2003;14:303-311. UI 12631634. [pmid: 12631634].
Schillinger M, Mlekusch W, Wolfram RM, Budinsky AC, Exner M, Rumpold H, et al. Endovascular brachytherapy: effect on acute inflammatory response after percutaneous femoropopliteal arterial interventions. Radiology. 2004;230:556-560. UI 14752194. [pmid: 14752194].
Schillinger M, Sabeti S, Dick P, Amighi J, Mlekusch W, Schlager O, et al. Sustained benefit at 2 years of primary femoropopliteal stenting compared with balloon angioplasty with optional stenting. Circulation. 2007;115:2745-2749. UI 17502568. [pmid: 17502568].
Schillinger M, Sabeti S, Loewe C, Dick P, Amighi J, Mlekusch W, et al. Balloon angioplasty versus implantation of nitinol stents in the superficial femoral artery. New England Journal of Medicine. 2006;354:1879-1888. UI 16672699. [pmid: 16672699].
Tetteroo E, Haaring C, van der GY, van Schaik JP, van Engelen AD, Mali WP. Intraarterial pressure gradients after randomized angioplasty or stenting of iliac artery lesions. Dutch Iliac Stent Trial Study Group. Cardiovascular & Interventional Radiology. 1996;19:411-417. UI 8994707. [pmid: 8994707].
Tetteroo E, van der GY, Bosch JL, van Engelen AD, Hunink MG, Eikelboom BC, et al. Randomised comparison of primary stent placement versus primary angioplasty followed by selective stent placement in patients with iliac-artery occlusive disease. Dutch Iliac Stent Trial Study Group. Lancet. 1998;351:1153-1159. UI 9643685. [pmid: 9643685].
Vroegindeweij D, Vos LD, Tielbeek AV, Buth J, vd Bosch HC. Balloon angioplasty combined with primary stenting versus balloon angioplasty alone in femoropopliteal obstructions: A comparative randomized study. Cardiovascular & Interventional Radiology. 1997;20:420-425. UI 9354709. [pmid: 9354709].
Wolfram RM, Budinsky AC, Pokrajac B, Potter R, Minar E. Vascular brachytherapy with 192Ir after femoropopliteal stent implantation in high-risk patients: twelve-month follow-up results from the Vienna-5 trial. Radiology. 2005;236:343-351. UI 15987985. [pmid: 15987985].
Zabakis P, Kardamakis DM, Siablis D, Kalogeropoulou C, Karnabatidis D, Malatara G, et al. External beam radiation therapy reduces the rate of re-stenosis in patients treated with femoral stenting: results of a randomised study. Radiotherapy & Oncology. 2005;74:11-16. UI 15683662. [pmid: 15683662].
Zdanowski Z, Albrechtsson U, Lundin A, Jonung T, Ribbe E, Thorne J, et al. Percutaneous transluminal angioplasty with or without stenting for femoropopliteal occlusions? A randomized controlled study. International Angiology. 1999;18:251-255. UI 10811511. [pmid: 10811511].

## Nonrandomized comparative studies that evaluate PTA

Aschauer M, Hausegger KA, Lammer J, Klein GE, Fluckiger F, Lafer M, et al. [Percutaneous recanalization of iliac artery occlusions--retrospective analysis before and following availability of stents]. [German]. Vasa- Supplementum. 1991;33:197-198. UI 1838635. [pmid: 1838635].
Ballard JL, Bergan JJ, Singh P, Yonemoto H, Killeen JD. Aortoiliac stent deployment versus surgical reconstruction: analysis of outcome and cost. Journal of Vascular Surgery. 101(28):94-101. UI 9685135.
Becquemin JP, Allaire E, Qvarfordt P, Desgranges P, Kobeiter H, Melliere D. Surgical transluminal iliac angioplasty with selective stenting: long-term results assessed by means of duplex scanning. Journal of Vascular Surgery. 1999;29:422-429. UI 10069906. [pmid: 10069906].
Bosch JL, Haaring C, Meyerovitz MF, Cullen KA, Hunink MG. Cost-effectiveness of percutaneous treatment of iliac artery occlusive disease in the United States. AJR. 2000;American:517-521. UI 10915706. [pmid: 10915706].
Bosch JL, Tetteroo E, Mali WP, Hunink MG. Iliac arterial occlusive disease: cost-effectiveness analysis of stent placement versus percutaneous transluminal angioplasty. Dutch Iliac Stent Trial Study Group. Radiology. 1998;208:641-648. UI 9722840. [pmid: 9722840].
Bosiers M, Hart JP, Deloose K, Verbist J, Peeters P. Endovascular therapy as the primary approach for limb salvage in patients with critical limb ischemia: experience with 443 infrapopliteal procedures. Vascular. 2006;14:63-69. UI 16956473. [pmid: 16956473].
Cambria RA, Farooq MM, Mewissen MW, Freischlag JA, Seabrook GR, Crain MR, et al. Endovascular therapy of iliac arteries: routine application of intraluminal stents does not improve clinical patency. Annals of Vascular Surgery. 1999;13:599-605. UI 10541614. [pmid: 10541614].
Cejna M, Schoder M, Lammer J. [PTA vs. stent in femoropopliteal obstruction]. [German]. Radiologe. 1999;39:144-150. UI 10093840. [pmid: 10093840].
Cho L, Roffi M, Mukherjee D, Bhatt DL, Bajzer C, Yadav JS. Superficial femoral artery occlusion: nitinol stents achieve better flow and reduce the need for medications than balloon angioplasty alone. Journal of Invasive Cardiology. 2003;15:198-200. UI 12668846. [pmid: 12668846].
Costanza MJ, Queral LA, Lilly MP, Finn WR. Hemodynamic outcome of endovascular therapy for TransAtlantic InterSociety Consensus type B femoropopliteal arterial occlusive lesions. Journal of Vascular Surgery. 2004;39:343-350. UI 14743134. [pmid: 14743134].
d'Othee BJ, Haulon S, Mounier-Vehier C, Beregi JP, Jabourek O, Willoteaux S. Percutaneous endovascular treatment for stenoses and occlusions of infrarenal aorta and aortoiliac bifurcation: midterm results. European Journal of Vascular & Endovascular Surgery. 2002;24:516-523. UI 12443747. [pmid: 12443747].
d'Othee BJ, Langdon DR, Bell GK, Bettmann MA. Operating expenses for the diagnosis and treatment of peripheral vascular disease in an academic interventional radiology department: cost calculations according to a microeconomic method. Journal of Vascular & Interventional Radiology. 2006;17:85-94. UI 16415137. [pmid: 16415137].
Do DD, Triller J, Walpoth BH, Stirnemann P, Mahler F. A comparison study of self-expandable stents vs balloon angioplasty alone in femoropopliteal artery occlusions. Cardiovascular & Interventional Radiology. 1992;15:306-312. UI 1423391. [pmid: 1423391].
Hassen-Khodja R, Sala F, Declemy S, Bouillanne PJ, Batt M, Staccini P. Value of stent placement during percutaneous transluminal angioplasty of the iliac arteries. Journal of Cardiovascular Surgery. 2001;42:369-374. UI 11398035. [pmid: 11398035].
Kalbaugh CA, Taylor SM, Blackhurst DW, Dellinger MB, Trent EA, Youkey JR. One-year prospective quality-of-life outcomes in patients treated with angioplasty for symptomatic peripheral arterial disease. Journal of Vascular Surgery. 302(44):296-302. UI 16814976.
Kudo T, Chandra FA, Ahn SS. Long-term outcomes and predictors of iliac angioplasty with selective stenting. Journal of Vascular Surgery. 2005;42:466-475. UI 16171589. [pmid: 16171589].
Lasry JL, Boyer JC, Bories H, Kadouch R, Lagneau P. [Results of endoprostheses in the iliac arteries; an experience apropos of 47 implantations]. [French]. Archives des Maladies du Coeur et des Vaisseaux. 1994;87:1195-1200. UI 7646233. [pmid: 7646233].
Laxdal E, Wirsching J, Jenssen GL, Pedersen G, Aune S, Daryapeyma A. Endovascular treatment of isolated atherosclerotic lesions of the infrarenal aorta is technically feasible with acceptable long-term results. European Journal of Radiology. 2007;61:541-544. UI 17258418. [pmid: 17258418].
Maspes F, Innocenzi L, Ascoli MA, Cossu E, Squillaci E, Pistolese GR, et al. [Percutaneous transluminal angioplasty in the treatment of iliac stenosis. The authors' new guideline for 100 patients]. [Italian]. Radiologia Medica. 1995;90:772-780. UI 8685462. [pmid: 8685462].
Pozzi MF, Fisicaro M, Calderan L, Malacrea M, Mazzone C, Cattin L, et al. Percutaneous revascularization of femoropopliteal artery disease: PTA and PTA plus stent. Results after six years' follow-up. Radiologia Medica. 2003;105:339-349. UI 12835627. [pmid: 12835627].
Sabeti S, Schillinger M, Amighi J, Sherif C, Mlekusch W, Ahmadi R, et al. Primary patency of femoropopliteal arteries treated with nitinol versus stainless steel self-expanding stents: propensity score-adjusted analysis. Radiology. 2004;232:516-521. UI 15286322. [pmid: 15286322].
Schillinger M, Exner M, Mlekusch W, Haumer M, Ahmadi R, Rumpold H, et al. Balloon angioplasty and stent implantation induce a vascular inflammatory reaction. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2002;9:59-66. UI 11958327.
Schillinger M, Exner M, Mlekusch W, Rumpold H, Ahmadi R, Sabeti S, et al. Fibrinogen predicts restenosis after endovascular treatment of the iliac arteries. Thrombosis & Haemostasis. 2002;87:959-965. UI 12083502. [pmid: 12083502].
Schillinger M, Mlekusch W, Haumer M, Sabeti S, Ahmadi R, Minar E. Angioplasty and elective stenting of de novo versus recurrent femoropopliteal lesions;:1-year follow-up. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2003;10:288-297. UI 12877612.
Schlager O, Dick P, Sabeti S, Amighi J, Mlekusch W, Minar E, et al. Long-segment SFA stenting--the dark sides: in-stent restenosis, clinical deterioration, and stent fractures. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2005;12:676-684. UI 16363897.
Schneider PA, Abcarian PW, Ogawa DY, Leduc JR, Wright PW. Should balloon angioplasty and stents have any role in operative intervention for lower extremity ischemia?. Annals of Vascular Surgery. 1997;11:574-580. UI 9363302. [pmid: 9363302].
Siablis D, Karnabatidis D, Katsanos K, Kagadis GC, Kraniotis P, Diamantopoulos A, et al. Sirolimus-eluting versus bare stents after suboptimal infrapopliteal angioplasty for critical limb ischemia: enduring 1-year angiographic and clinical benefit. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2007;14:241-250. UI 17484536.
Siablis D, Kraniotis P, Karnabatidis D, Kagadis GC, Katsanos K, Tsolakis J. Sirolimus-eluting versus bare stents for bailout after suboptimal infrapopliteal angioplasty for critical limb ischemia: 6-month angiographic results from a nonrandomized prospective single-center study. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2005;12:685-695. UI 16363898.
Steckmeier B, Parzhuber A, Verrel F, Kellner W, Reininger C. [Simultaneous vascular and endovascular surgery of complex vascular diseases]. [German]. Langenbecks Archiv fur Chirurgie -Supplement - Kongressband. 1998;115:532-537. UI 9931673.
Steidle B. [Preventive percutaneous radiotherapy for avoiding hyperplasia of the intima following angioplasty together with stent implantation]. [German]. Strahlentherapie und Onkologie. 1994;170:151-154. UI 8160095. [pmid: 8160095].
Thalhammer A, Balzer J, Jacobi V, Vogl T. [Stents in the iliac arteries: a minimally invasive method]. [German]. Hamostaseologie. 2003;23:67-70. UI 12736701. [pmid: 12736701].
Therasse E, Cote G, Oliva VL, Cusson JR, Wistaff R, Nguyen PV, et al. Infrarenal aortic stenosis: value of stent placement after percutaneous transluminal angioplasty failure. Radiology. 2001;219:655-662. UI 11376250. [pmid: 11376250].
Timaran CH, Ohki T, Gargiulo NJ III, Veith FJ, Stevens SL, Freeman MB, et al. Iliac artery stenting in patients with poor distal runoff: Influence of concomitant infrainguinal arterial reconstruction. Journal of Vascular Surgery. 484(38):479-484. UI 12947261.
Timaran CH, Prault TL, Stevens SL, Freeman MB, Goldman MH. Iliac artery stenting versus surgical reconstruction for TASC (TransAtlantic Inter-Society Consensus) type B and type C iliac lesions. Journal of Vascular Surgery. 2003;38:272-278. UI 12891108. [pmid: 12891108].
Trocciola SM, Chaer R, Dayal R, Lin SC, Kumar N, Rhee J, et al. Comparison of results in endovascular interventions for infrainguinal lesions: claudication versus critical limb ischemia. American Surgeon. 479(71):474-479. UI 16044925.
Vogt KJ, Rasmussen JG, Just S, Schroeder TV. Effect and outcome of balloon angioplasty and stenting of the iliac arteries evaluated by intravascular ultrasound. European Journal of Vascular & Endovascular Surgery. 1999;17:47-55. UI 10071617. [pmid: 10071617].
Westcott MA, Bonn J. Comparison of conventional angioplasty with the Palmaz stent in the treatment of abdominal aortic stenoses from the STAR registry. SCVIR Transluminal Angioplasty and Revascularization. Journal of Vascular & Interventional Radiology. 1998;9:225-231. UI 9540904. [pmid: 9540904].
Whatling PJ, Gibson M, Torrie EP, Magee TR, Galland RB. Iliac occlusions: stenting or crossover grafting? An examination of patency and cost. European Journal of Vascular & Endovascular Surgery. 2000;20:36-40. UI 10906295. [pmid: 10906295].
Zan S, Varetto G, Maselli M, Conforti M, Moniaci D, Scovazzi P. [Therapeutic approach to the unilateral occlusive iliac artery disease. Preliminary results]. [Italian]. Minerva Cardioangiologica. 2003;51:71-77. UI 12652263. [pmid: 12652263].

## Case control studies that evaluate stent

Hausegger KA, Lammer J, Klein GE, Fluckiger F, Lafer M, Pilger E, et al. [Percutaneous recanalization of pelvic artery occlusions�fibrinolysis, PTA, stents]. [German]. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 1991;155:550-555. UI 1837240. [pmid: 1837240].

## RCTs that evaluate bypass

Abbott WM, Green RM, Matsumoto T, Wheeler JR, Miller N, Veith FJ, et al. Prosthetic above-knee femoropopliteal bypass grafting: results of a multicenter randomized prospective trial. Above-Knee Femoropopliteal Study Group. Journal of Vascular Surgery. 1997;25:19-28. UI 9013904. [pmid: 9013904].
Ahn S, Rutherford RB. A multicenter prospective randomized trial to determine the optimal treatment of patients with claudication and isolated superficial femoral artery occlusive disease: conservative versus endovascular versus surgical therapy. Journal of Vascular Surgery. 1992;15:889-891. UI 1533686. [pmid: 1533686].
Ballotta E, Renon L, De RA, Barbon B, Terranova O, Da GG. Prospective randomized study on reversed saphenous vein infrapopliteal bypass to treat limb-threatening ischemia: common femoral artery versus superficial femoral or popliteal and tibial arteries as inflow. Journal of Vascular Surgery. 2004;40:732-740. UI 15472602. [pmid: 15472602].
Ballotta E, Renon L, Toffano M, Da GG. Prospective randomized study on bilateral above-knee femoropopliteal revascularization: Polytetrafluoroethylene graft versus reversed saphenous vein. Journal of Vascular Surgery. 2003;38:1051-1055. UI 14603216. [pmid: 14603216].
Bergan JJ, Wilson SE, Wolf G, Deupree RH. Unexpected, late cardiovascular effects of surgery for peripheral artery disease. Veterans Affairs Cooperative Study 199. Archives of Surgery. 1992;127:1119-1123. UI 1387528. [pmid: 1387528].
Bew SA, Bryant AE, Desborough JP, Hall GM. Epidural analgesia and arterial reconstructive surgery to the leg: effects on fibrinolysis and platelet degranulation. British Journal of Anaesthesia. 2001;86:230-235. UI 11573665. [pmid: 11573665].
Braithwaite BD, Davies B, Heather BP, Earnshaw JJ. Early results of a randomized trial of rifampicin-bonded Dacron grafts for extra-anatomic vascular reconstruction. Joint Vascular Research Group. British Journal of Surgery. 1998;85:1378-1381. UI 9782018. [pmid: 9782018].
Burger DH, Kappetein AP, van Bockel JH, Breslau PJ. A prospective randomized trial comparing vein with polytetrafluoroethylene in above-knee femoropopliteal bypass grafting. Journal of Vascular Surgery. 2000;32:278-283. UI 10917987. [pmid: 10917987].
Clair DG, Golden MA, Mannick JA, Whittemore AD, Donaldson MC. Randomized prospective study of angioscopically assisted in situ saphenous vein grafting. Journal of Vascular Surgery. 1994;19:992-999. UI 8201718. [pmid: 8201718].
Cole CW, Bormanis J, Luna GK, Hajjar G, Barber GG, Harris KA, et al. Ancrod versus heparin for anticoagulation during vascular surgical procedures. Journal of Vascular Surgery. 293(17):288-292. UI 8433424.
de DG, Weber G, de DG. Minimally invasive or conventional aorto-bifemoral by-pass. A randomised study. European Journal of Vascular & Endovascular Surgery. 2002;24:485-491. UI 12443742. [pmid: 12443742].
Devine C, McCollum C. North West Femoro-Popliteal Trial Participants. Heparin-bonded Dacron or polytetrafluorethylene for femoropopliteal bypass: five-year results of a prospective randomized multicenter clinical trial. Journal of Vascular Surgery. 2004;40:924-931. UI 15557906. [pmid: 15557906].
Eiberg JP, Roder O, Stahl-Madsen M, Eldrup N, Qvarfordt P, Laursen A, et al. Fluoropolymer-coated dacron versus PTFE grafts for femorofemoral crossover bypass: randomised trial. European Journal of Vascular & Endovascular Surgery. 2006;32:431-438. UI 16807001. [pmid: 16807001].
Fourneau I, Sabbe T, Daenens K, Nevelsteen A. Hand-assisted laparoscopy versus conventional median laparotomy for aortobifemoral bypass for severe aorto-iliac occlusive disease: a prospective randomised study. European Journal of Vascular & Endovascular Surgery. 2006;32:645-650. UI 16863695. [pmid: 16863695].
Fujioka K, Esato K, Zempo N. Effect of elastase on primary graft patency after femoralpopliteal arterial bypass for arteriosclerosis obliterans: a randomized, controlled study. International Surgery. 1997;82:94-97. UI 9189814. [pmid: 9189814].
Gaspard DJ, Cohen JL, Gaspar MR. Aortoiliofemoral thromboendarterectomy vs bypass graft. A randomized study. Archives of Surgery. 1972;105:898-901. UI 4264387. [pmid: 4264387].
Green RM, Abbott WM, Matsumoto T, Wheeler JR, Miller N, Veith FJ, et al. Prosthetic above-knee femoropopliteal bypass grafting: five-year results of a randomized trial. Journal of Vascular Surgery. 2000;31:417-425. UI 10709052. [pmid: 10709052].
Griffiths GD, Nagy J, Black D, Stonebridge PA. Randomized clinical trial of distal anastomotic interposition vein cuff in infrainguinal polytetrafluoroethylene bypass grafting. British Journal of Surgery. 2004;91:560-562. UI 15122605. [pmid: 15122605].
Harris PL, How TV, Jones DR. Prospectively randomized clinical trial to compare in situ and reversed saphenous vein grafts for femoropopliteal bypass. British Journal of Surgery. 1987;74:252-255. UI 3555691. [pmid: 3555691].
Johnson WC, Lee KK. A comparative evaluation of polytetrafluoroethylene, umbilical vein, and saphenous vein bypass grafts for femoral-popliteal above-knee revascularization: a prospective randomized Department of Veterans Affairs cooperative study. Journal of Vascular Surgery. 2000;32:268-277. UI 10917986. [pmid: 10917986].
Kapfer X, Meichelboeck W, Groegler FM. Comparison of carbon-impregnated and standard ePTFE prostheses in extra-anatomical anterior tibial artery bypass: a prospective randomized multicenter study. European Journal of Vascular & Endovascular Surgery. 2006;32:155-168. UI 16617028. [pmid: 16617028].
Kedora J, Hohmann S, Garrett W, Munschaur C, Theune B, Gable D. Randomized comparison of percutaneous Viabahn stent grafts vs prosthetic femoral-popliteal bypass in the treatment of superficial femoral arterial occlusive disease. Journal of Vascular Surgery. 1916;45:10-16. UI 17126520. [pmid: 17126520].
Klinkert P, Schepers A, Burger DH, van Bockel JH, Breslau PJ. Vein versus polytetrafluoroethylene in above-knee femoropopliteal bypass grafting: five-year results of a randomized controlled trial. Journal of Vascular Surgery. 2003;37:149-155. UI 12514593. [pmid: 12514593].
Kohler TR, Kaufman JL, Kacoyanis G, Clowes A, Donaldson MC, Kelly E, et al. Effect of aspirin and dipyridamole on the patency of lower extremity bypass grafts. Surgery. 1984;96:462-466. UI 6474351. [pmid: 6474351].
Kretschmer G, Herbst F, Prager M, Sautner T, Wenzl E, Berlakovich GA, et al. A decade of oral anticoagulant treatment to maintain autologous vein grafts for femoropopliteal atherosclerosis. Archives of Surgery. 1992;127:1112-1115. UI 1514915. [pmid: 1514915].
Kretschmer G, Holzenbein TJ. Oral anticoagulation in peripheral vascular surgery: how intense, for how long, or at all?. Journal of Internal Medicine. 1999;245:389-397. UI 10356602. [pmid: 10356602].
Kretschmer G, Wenzl E, Huk I, Polterauer P, Ehringer H, Minar E, et al. RCTs that evaluate bypass[Role of postoperative anticoagulant treatment following femoro-popliteal venous bypass. Interim evaluation of a controlled clinical study]. [German]. Wiener Klinische Wochenschrift. 1987;99:591-595. UI 2445114. [pmid: 2445114].
Kretschmer G, Wenzl E, Schemper M, Polterauer P, Ehringer H, Marcosi L, et al. Influence of postoperative anticoagulant treatment on patient survival after femoropopliteal vein bypass surgery. Lancet. 1988;1:797-799. UI 2895319. [pmid: 2895319].
Kretschmer G, Wenzl E, Wagner O, Polterauer P, Ehringer H, Minar E, et al. Influence of anticoagulant treatment in preventing graft occlusion following saphenous vein bypass for femoropopliteal occlusive disease. British Journal of Surgery. 1986;73:689-692. UI 3530366. [pmid: 3530366].
Kujath P, Eckmann C, Misselwitz F. Low-molecular-weight heparin in arterial reconstructive surgery: a double-blind, randomized dose-finding trial. Clinical & Applied Thrombosis/Hemostasis. 2002;8:337-345. UI 12516683. [pmid: 12516683].
Laurila K, Lepantalo M, Teittinen K, Kantonen I, Forssell C, Vilkko P, et al. Does an adjuvant AV-fistula improve the patency of a femorocrural PTFE bypass with distal vein cuff in critical leg ischaemia?--a prospective randomised multicentre trial. European Journal of Vascular & Endovascular Surgery. 2004;27:180-185. UI 14718901. [pmid: 14718901].
Lundell A, Lindblad B, Bergqvist D, Hansen F. Femoropopliteal-crural graft patency is improved by an intensive surveillance program: a prospective randomized study. Journal of Vascular Surgery. 1933;21:26-33. UI 7823359. [pmid: 7823359].
Malmstedt J, Takolander R, Wahlberg E. A randomized prospective study of valvulotome efficacy in in situ reconstructions. European Journal of Vascular & Endovascular Surgery. 2005;30:52-56. UI 15933983. [pmid: 15933983].
Miller A, Marcaccio EJ, Tannenbaum GA, Kwolek CJ, Stonebridge PA, Lavin PT, et al. Comparison of angioscopy and angiography for monitoring infrainguinal bypass vein grafts: results of a prospective randomized trial. Journal of Vascular Surgery. 396(17):382-396. UI 8433433.
Mohammadi TA, Warmer de WG, Rhissassi B. Comparing vein with collagen impregnated woven polyester prosthesis in above-knee femoropopliteal bypass grafting. International Journal Of Surgery. 2007;5:109-113. UI 17448975. [pmid: 17448975].
Moody AP, Edwards PR, Harris PL. In situ versus reversed femoropopliteal vein grafts: long-term follow-up of a prospective, randomized trial. British Journal of Surgery. 1992;79:750-752. UI 1393459. [pmid: 1393459].
Nehler MR, Brass EP, Anthony R, Dormandy J, Jiao J, McNamara TO, et al. Adjunctive parenteral therapy with lipo-ecraprost, a prostaglandin El analog, in patients with critical limb ischemia undergoing distal revascularization does not improve 6-month outcomes. Journal of Vascular Surgery. 960(45):953-960. UI 17350216.
Panneton JM, Hollier LH, Hofer JM. Multicenter randomized prospective trial comparing a pre-cuffed polytetrafluoroethylene graft to a vein cuffed polytetrafluoroethylene graft for infragenicular arterial bypass. Annals of Vascular Surgery. 2004;18:199-206. UI 15253256. [pmid: 15253256].
Pereira CE, Albers M, Romiti M, Brochado-Neto FC, Pereira CA. Meta-analysis of femoropopliteal bypass grafts for lower extremity arterial insufficiency. Journal of Vascular Surgery. 2006;44:510-517. UI 16950427. [pmid: 16950427].
Pierce ET, Pomposelli FB Jr, Stanley GD, Lewis KP, Cass JL, LoGerfo FW, et al. Anesthesia type does not influence early graft patency or limb salvage rates of lower extremity arterial bypass. Journal of Vascular Surgery. 232(25):226-232. UI 9052557.
Post S, Kraus T, Muller-Reinartz U, Weiss C, Kortmann H, Quentmeier A, et al. Dacron vs. polytetrafluoroethylene grafts for femoropopliteal bypass: a prospective randomised multicentre trial. European Journal of Vascular & Endovascular Surgery. 2001;22:226-231. UI 11506515. [pmid: 11506515].
Prager M, Polterauer P, Bohmig HJ, Wagner O, Fugl A, Kretschmer G, et al. Collagen versus gelatin-coated Dacron versus stretch polytetrafluoroethylene in abdominal aortic bifurcation graft surgery: results of a seven-year prospective, randomized multicenter trial. Surgery. 2001;130:408-414. UI 11562661. [pmid: 11562661].
Prager MR, Hoblaj T, Nanobashvili J, Sporn E, Polterauer P, Wagner O, et al. Collagen- versus gelatine-coated Dacron versus stretch PTFE bifurcation grafts for aortoiliac occlusive disease: long-term results of a prospective, randomized multicenter trial. Surgery. 2003;134:80-85. UI 12874586. [pmid: 12874586].
Robinson BI, Fletcher JP. Australian and New Zealand Femoropopliteal Graft Trial Participants. Fluoropolymer coated Dacron or polytetrafluoroethylene for femoropopliteal bypass grafting: a multicentre trial. ANZ Journal of Surgery. 2003;73:95-99. UI 12608965. [pmid: 12608965].
Schouten O, Hoedt MT, Wittens CH, Hop WC, van Sambeek MR, van UH, et al. End-to-end versus end-to-side distal anastomosis in femoropopliteal bypasses; results of a randomized multicenter trial. European Journal of Vascular & Endovascular Surgery. 2005;29:457-462. UI 15966083. [pmid: 15966083].
Schulman ML, Badhey MR, Yatco R. Superficial femoral-popliteal veins and reversed saphenous veins as primary femoropopliteal bypass grafts: a randomized comparative study. Journal of Vascular Surgery. 1987;6:1-10. UI 3599276. [pmid: 3599276].
Schulman ML, Badhey MR, Yatco R, Pillari G. An 11-year experience with deep leg veins as femoropopliteal bypass grafts. Archives of Surgery. 1986;121:1010-1015. UI 3741095. [pmid: 3741095].
Smith FC, Thomson IA, Hickey NC, Paterson IS, Tsang GM, Simms MH, et al. Adjuvant prostanoid treatment during femorodistal reconstruction. Annals of Vascular Surgery. 1993;7:88-94. UI 7686028. [pmid: 7686028].
Tilanus HW, Obertop H, van UH. Saphenous vein or PTFE for femoropopliteal bypass. A prospective randomized trial. Annals of Surgery. 1985;202:780-782. UI 3907550. [pmid: 3907550].
van der Zaag ES, Legemate DA, Prins MH, Reekers JA, Jacobs MJ. Angioplasty or bypass for superficial femoral artery disease? A randomised controlled trial. European Journal of Vascular & Endovascular Surgery. 2004;28:132-137. UI 15234692. [pmid: 15234692].
van der Zaag ES, Prins MH, Jacobs MJ. [Treatment of intermittent claudication; prospective randomized study in the BAESIC-Trial (bypass, angioplasty or endarterectomy patients with severe intermittent claudication)]. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1996;140:787-788. UI 8668267. [pmid: 8668267].
Veith FJ, Gupta SK, Ascer E, White-Flores S, Samson RH, Scher LA, et al. Six-year prospective multicenter randomized comparison of autologous saphenous vein and expanded polytetrafluoroethylene grafts in infrainguinal arterial reconstructions. Journal of Vascular Surgery. 1986;3:104-114. UI 3510323. [pmid: 3510323].
Watelet J, Cheysson E, Poels D, Menard JF, Papion H, Saour N, et al. In situ versus reversed saphenous vein for femoropopliteal bypass: a prospective randomized study of 100 cases. Annals of Vascular Surgery. 1987;1:441-452. UI 3504357. [pmid: 3504357].
Watelet J, Soury P, Menard JF, Plissonnier D, Peillon C, Lestrat JP, et al. Femoropopliteal bypass: in situ or reversed vein grafts? Ten-year results of a randomized prospective study. Annals of Vascular Surgery. 1997;11:510-519. UI 9302064. [pmid: 9302064].
Weaver FA, Comerota AJ, Youngblood M, Froehlich J, Hosking JD, Papanicolaou G. Surgical revascularization versus thrombolysis for nonembolic lower extremity native artery occlusions: results of a prospective randomized trial. The STILE Investigators. Surgery versus Thrombolysis for Ischemia of the Lower Extremity. Journal of Vascular Surgery. 521(24):513-521. UI 8911400.
Wengerter KR, Veith FJ, Gupta SK, Goldsmith J, Farrell E, Harris PL, et al. Prospective randomized multicenter comparison of in situ and reversed vein infrapopliteal bypasses. Journal of Vascular Surgery. 197(13):189-197. UI 1990160.
Wilson SE, Wolf GL, Cross AP. Percutaneous transluminal angioplasty versus operation for peripheral arteriosclerosis. Report of a prospective randomized trial in a selected group of patients. Journal of Vascular Surgery. 1989;9:1-9. UI 2521362. [pmid: 2521362].
Wilson YG, Davies AH, Currie IC, McGrath C, Morgan M, Baird RN, et al. Angioscopically-assisted in situ saphenous vein bypass for infrainguinal revascularisation. European Journal of Vascular & Endovascular Surgery. 1996;12:223-229. UI 8760987. [pmid: 8760987].

## Nonrandomized comparative studies that evaluate bypass

Comparative evaluation of prosthetic, reversed, and in situ vein bypass grafts in distal popliteal and tibial-peroneal revascularization. Veterans Administration Cooperative Study Group 141. Archives of Surgery. 1988;123:434-438. UI 3348735. [pmid: 3348735].
Abashkin VN. [Comparative evaluation of the results of auto- and allovenous shunting of femoro-popliteal arteries]. [Russian]. Klinicheskaia Khirurgiia. 1986:70-71. UI 3761894. [pmid: 3761894].
AbuRahma AF, Robinson PA, Holt SM. Prospective controlled study of polytetrafluoroethylene versus saphenous vein in claudicant patients with bilateral above knee femoropopliteal bypasses. Surgery. 601(126):594-601. UI 10520903.
Al-Omran M, Tu JV, Johnston KW, Mamdani MM, Kucey DS. Outcome of revascularization procedures for peripheral arterial occlusive disease in Ontario between 1991 and 1998: a population-based study. Journal of Vascular Surgery. 2003;38:279-288. UI 8795511. [pmid: 12891109].
Alexander JJ, Wells KE, Yuhas JP, Piotrowski JJ. The role of composite sequential bypass in the treatment of multilevel infrainguinal arterial occlusive disease. American Journal of Surgery. 1996;172:118-122. UI 9257667. [pmid: 8795511].
Alimi Y, Di MP, Barthelemy P, Juhan C. Iliac transluminal angioplasty and distal surgical revascularisation can be performed in a one-step technique. International Angiology. 1997;16:83-87. UI 8733871. [pmid: 9257667].
Allen BT, Reilly JM, Rubin BG, Thompson RW, Anderson CB, Flye MW, et al. Femoropopliteal bypass for claudication: vein vs. PTFE. Annals of Vascular Surgery. 1996;10:178-185. UI 2577604. [pmid: 8733871].
Allenberg JR, Maeder N, Meybier H. [Femoro-crural bypass-- orthotopic]. [German]. Langenbecks Archiv fur Chirurgie -Supplement II - Verhandlungen der Deutschen Gesellschaft fur Chirurgie. 1989:607-612. UI 12891109.
Alpagut U, Kalko Y, Basaran M, Dayioglu E. A comparison between minilaparotomy and standard median laparotomy for reconstruction of aorto-iliac occlusive disease. Acta Chirurgica Belgica. 2003;103:208-211. UI 12768865. [pmid: 12768865].
Aslanov AD, Mikhalov IP, Zhulin DV, Logvina OE, Taukenova LI, Akhmetov AV. [Comparative assessment of different methods of treatment of chronic critical ischemia of lower extremities in elderly and senile patients].[Russian]. Vestnik Khirurgii Imeni i - i - Grekova. 2003;162:83-86. UI 14569786. [pmid: 14569786].
Ballard JL, Bergan JJ, Singh P, Yonemoto H, Killeen JD. Aortoiliac stent deployment versus surgical reconstruction: analysis of outcome and cost. Journal of Vascular Surgery. 101(28):94-101. UI 9685135.
Batt M, Declemy S, Persch M, Hassen-Khodja R, Daune B, Avril G, et al. Synchronous reconstruction for combined aortoiliac and femoropopliteal occlusive lesions. The role of proximal bypass. Journal of Cardiovascular Surgery. 1990;31:448-452. UI 2211797. [pmid: 2211797].
Becquemin JP, Cavillon A, Allaire E, Haiduc F, Desgranges P. Iliac and femoropopliteal lesions: evaluation of balloon angioplasty and classical surgery. Journal of Endovascular Surgery. 1995;2:42-50. UI 9234117. [pmid: 9234117].
Becquemin JP, Haiduc F, Labastie J, Melliere D. Femoropopliteal in situ saphenous vein bypass: technical aspects and factors determining patency. Annals of Vascular Surgery. 1987;1:432-440. UI 3504356. [pmid: 3504356].
Benhamou AC, Acquaviva P, Zerez A, Castellani L, Alison D. [Peroperative endoluminal dilatation or recanalization (DELPO or RCPO) in arteriopathies of the lower extremities. A new therapeutic weapon for the vascular surgeon. Apropos of 42 cases]. [French]. Journal des Maladies Vasculaires. 1986;11:379-387. UI 2949036. [pmid: 2949036].
Bennion RS, Williams RA, Stabile BE, Fox MA, Owens ML, Wilson SE. Patency of autogenous saphenous vein versus polytetrafluoroethylene grafts in femoropopliteal bypass for advanced ischemia of the extremity. Surgery, Gynecology & Obstetrics. 1985;160:239-242. UI 3975795.
Bergamini TM, George SM Jr, Massey HT, Henke PK, Klamer TW, Lambert GE Jr, et al. Pedal or peroneal bypass: which is better when both are patent?. Journal of Vascular Surgery. 355(20):347-355. UI 8084026.
Berglund J, Bjorck M, Elfstrom J. SWEDVASC Femoro-popliteal Study Group. Long-term results of above knee femoro-popliteal bypass depend on indication for surgery and graft-material. European Journal of Vascular & Endovascular Surgery. 2005;29:412-418. UI 15776397. [pmid: 15776397].
Bergmark C, Johansson G, Olofsson P, Swedenborg J. Femoropopliteal and femoro-distal bypass: a comparison between in situ and reversed technique. Journal of Cardiovascular Surgery. 1991;32:117-120. UI 2010440. [pmid: 2010440].
Berlakovich GA, Herbst F, Mittlbock M, Kretschmer G. The choice of material for above-knee femoropopliteal bypass. A 20-year experience. Archives of Surgery. 1994;129:297-302. UI 8129607. [pmid: 8129607].
Blair JM, Gewertz BL, Moosa H, Lu CT, Zarins CK. Percutaneous transluminal angioplasty versus surgery for limb-threatening ischemia. Journal of Vascular Surgery. 1989;9:698-703. UI 2524606. [pmid: 2524606].
Bosch JL, Halpern EF, Gazelle GS. Comparison of preference-based utilities of the Short-Form 36 Health Survey and Health Utilities Index before and after treatment of patients with intermittent claudication. Medical Decision Making. 2002;22:403-409. UI 12365482. [pmid: 12365482].
Bradley KJ, Skotnicky SH, Buskens F, Kuypers PJ. Comparative study of venous patches and bypasses in femoro popliteal arterial surgery. Journal of Cardiovascular Surgery. 1971;12:27-29. UI 5091631. [pmid: 5091631].
Cacciatore R, Inderbitzi R, Stirnemann P. [Five years experience with infra-inguinal arterial reconstruction: a comparison of venous with PTFE bypass]. [German]. Vasa. 1992;21:171-176. UI 1621437. [pmid: 1621437].
Calligaro KD, Syrek JR, Dougherty MJ, Rua I, Raviola CA, DeLaurentis DA. Use of arm and lesser saphenous vein compared with prosthetic grafts for infrapopliteal arterial bypass: are they worth the effort?. Journal of Vascular Surgery. 925(26):919-924. UI 9423706.
Caparoski R, Kaftandziev D, Colanceski V, Vitanov A, Dimitrov V, Savevski J, et al. [Results of reconstructive bypass surgery of obliterative arteriosclerosis in the aortoiliac segment]. [Croatian]. Acta Chirurgica Iugoslavica. 1978;25:199-202. UI 654762. [pmid: 654762].
Chang JB, Stein TA. Infrainguinal revascularizations in octogenarians and septuagenarians. Journal of Vascular Surgery. 2001;34:133-138. UI 11436086. [pmid: 11436086].
Ciervo A, Dardik H, Qin F, Silvestri F, Wolodiger F, Hastings B, et al. The tourniquet revisited as an adjunct to lower limb revascularization. Journal of Vascular Surgery. 2000;31:436-442. UI 10709054. [pmid: 10709054].
Cole SE, Baird RN, Horrocks M, Jeans WD. The role of balloon angioplasty in the management of lower limb ischaemia. European Journal of Vascular Surgery. 1987;1:61-65. UI 2972562. [pmid: 2972562].
Connolly JE, Kwaan JH. In situ saphenous vein bypass. Archives of Surgery. 1982;117:1551-1557. UI 7149975. [pmid: 7149975].
Contreras F, Polterauer P, Kretschmer G, Kovats E, Waneck R, Schemper M, et al. Postoperative assessment of below-knee bypass grafts. Surgery, Gynecology & Obstetrics. 1984;158:339-343. UI 6710296.
Corson JD, Brewster DC, LaSalle AJ, Darling RC. Comparative analysis of vein and prosthetic bypass grafts to the isolated popliteal artery. Surgery. 1982;91:448-451. UI 7064100. [pmid: 7064100].
Courchia G, Serise JM, Moreau JL, Delorge C, Winnock S, Boissieras P. [Peroperative angiography in reparative surgery of the lower limbs. Apropos of experience with 1099 cases]. [French]. Journal des Maladies Vasculaires. 1988;13:11-19. UI 2964494. [pmid: 2964494].
Cranley JJ, Hafner CD. Newer prosthetic material compared with autogenous saphenous vein for occlusive arterial disease of the lower extremity. Surgery. 1981;89:2-7. UI 7466608. [pmid: 7466608].
Currie IC, Wilson YG, Baird RN, Lamont PM. Treatment of intermittent claudication: the impact on quality of life. European Journal of Vascular & Endovascular Surgery. 1995;10:356-361. UI 7552539. [pmid: 7552539].
Dalsing MC, Cockerill E, Deupree R, Wolf G, Wilson S. Outcome predictors in selection of balloon angioplasty or surgery for peripheral arterial occlusive disease. Veterans Administration Cooperative Study No. 199. Surgery. 643(110):636-643. UI 1833845.
Darling RC, Linton RR. Durability of femoropopliteal reconstructions. Endarterectomy versus vein bypass grafts. American Journal of Surgery. 1972;123:472-479. UI 5013767. [pmid: 5013767].
Davidovic LB, Markovic DM, Vojnovic BR, Lotina SI, Kostic DM, Cinara IS, et al. Femoro-popliteal reconstructions: 'in situ' versus 'reversed' technique. Cardiovascular Surgery. 2001;9:356-361. UI 11420160. [pmid: 11420160].
de Vries SO, Visser K, de Vries JA, Wong JB, Donaldson MC, Hunink MG. Intermittent claudication: cost-effectiveness of revascularization versus exercise therapy. Radiology. 2002;222:25-36. UI 11756701. [pmid: 11756701].
Dick F, Diehm N, Galimanis A, Husmann M, Schmidli J, Baumgartner I. Surgical or endovascular revascularization in patients with critical limb ischemia: influence of diabetes mellitus on clinical outcome. Journal of Vascular Surgery. 2007;45:751-761. UI 17306950. [pmid: 17306950].
Dosluoglu HH, O'Brien-Irr MS, Lukan J, Harris LM, Dryjski ML, Cherr GS. Does preferential use of endovascular interventions by vascular surgeons improve limb salvage, control of symptoms, and survival of patients with critical limb ischemia?. American Journal of Surgery. 2006;192:572-576. UI 17071186. [pmid: 17071186].
Duncan WC, Linton RR, Darling RC. Aortoiliofemoral atherosclerotic occlusive disease: comparative results of endarterectomy and Dacron bypass grafts. Surgery. 1971;70:974-984. UI 5124676. [pmid: 5124676].
Edwards WH, Mulherin JL Jr. The role of graft material in femorotibial bypass grafts. Annals of Surgery. 1980;191:721-726. UI 7387234. [pmid: 7387234].
Eugster T, Stierli P, Aeberhard P. Infrainguinal arterial reconstruction with autologous vein grafts: are the results for the in situ technique better than those of non-reversed bypass? A long-term follow-up study. Journal of Cardiovascular Surgery. 2001;42:221-226. UI 11292939. [pmid: 11292939].
Eugster T, Stierli P, Fischer G, Gurke L. Long-term results of infrainguinal arterial reconstruction with spliced veins are equal to results with non-spliced veins. European Journal of Vascular & Endovascular Surgery. 2001;22:152-156. UI 11472049. [pmid: 11472049].
Fadin BV. [Surgical procedures on aorto-iliac segment from mini-approach in chronic lower limb ischemia]. [Russian]. Khirurgiia. 2007:14-19. UI 17495825.
Faglia E, Clerici G, Clerissi J, Gabrielli L, Losa S, Mantero M, et al. Early and five-year amputation and survival rate of diabetic patients with critical limb ischemia: data of a cohort study of 564 patients. European Journal of Vascular & Endovascular Surgery. 2006;32:484-490. UI 16730466. [pmid: 16730466].
Feinberg RL, Winter RP, Wheeler JR, Gregory RT, Snyder SO Jr, Gayle RG, et al. The use of composite grafts in femorocrural bypasses performed for limb salvage: a review of 108 consecutive cases and comparison with 57 in situ saphenous vein bypasses. Journal of Vascular Surgery. 1990;12:257-263. UI 2398584. [pmid: 2398584].
Feinglass J, McCarthy WJ, Slavensky R, Manheim LM, Martin GJ. Functional status and walking ability after lower extremity bypass grafting or angioplasty for intermittent claudication: results from a prospective outcomes study. Journal of Vascular Surgery. 2000;31:t-103. UI 10642712.
Fichelle JM, Marzelle J, Colacchio G, Gigou F, Cormier F, Cormier JM. Infrapopliteal polytetrafluoroethylene and composite bypass: factors influencing patency. Annals of Vascular Surgery. 1995;9:187-196. UI 7786705. [pmid: 7786705].
Fisher RK, Kirkpatrick UJ, How TV, Brennan JA, Gilling-Smith GL, Harris PL. The distaflo graft: a valid alternative to interposition vein?[erratum appears in Eur J Vase Endovasc Surg. 2003 Jul;26(l):lll-2]. European Journal of Vascular & Endovascular Surgery. 2003;25:235-239. UI 12623335. [pmid: 12623335].
Florenes T, Zasada W, Pillgram-Larsen J, Dedichen H. [Autologous vein vs. human umbilical vein for femoropopliteal bypass]. [Norwegian]. Tidsskrift for Den Norske Laegeforening. 1993;113:2681-2683. UI 8266287. [pmid: 8266287].
Fujioka K, Toyota S, Furutani A, Akiyama N, Yoshimura K, Seyama K, et al. [The fate of patients with intermittent claudication-comparison of surgical and non-surgical treatment]. [Japanese]. Nippon Geka Gakkai Zasshi. 1992;Journal:1043-1045. UI 1470113. [pmid: 1470113].
Gannon MX, Simms MH, Goldman M. Does the in situ technique improve flow characteristics in femoropopliteal bypass?. Journal of Vascular Surgery. 1986;4:595-599. UI 3537343. [pmid: 3537343].
Geiger G, Hoevels J, Storz L, Bayer HP. Vascular grafts in below-knee femoro-popliteal bypass. A comparative study. Journal of Cardiovascular Surgery. 1984;25:523-529. UI 6239870. [pmid: 6239870].
Gentile AT, Lee RW, Moneta GL, Taylor LM, Edwards JM, Porter JM. Results of bypass to the popliteal and tibial arteries with alternative sources of autogenous vein. Journal of Vascular Surgery. 279(23):272-279. UI 8637104.
Green RM, Donarye C, DeWeese JA. Autogenous venous bypass grafts and limb salvage: 5-year results in 1971 and 1991. Cardiovascular Surgery. 1995;3:425-430. UI 7582999. [pmid: 7582999].
Gschwandtner ME, Minar E, Ahmadi A, Haumer M, Hulsmann M, Maca T, et al. Impact of different therapeutic alternatives in treatment of severe limb ischemia: experiences on 190 consecutive patients at a department of medical angiology. Vasa. 1999;28:271-278. UI 10611845. [pmid: 10611845].
Gusinski AV, Korovin IV, Lebedev LV, Sedov VM, Shlomin VV, Smirnov AD, et al. [Application of different textile vascular grafts in the aorto-femoral location and ways for their improvement]. [Russian]. Vestnik Khirurgii Imeni i - i - Grekova. 2002;161:90-95. UI 12528632.
Hachiya T, Kaneko H, Shiraishi A, Unno N, Baba S, Sakaguchi S, et al. [Principle of treatment of intermittent claudication due to arteriosclerosis obliterans--reconstruction or conservative treatment]. [Japanese]. Nippon Geka Gakkai Zasshi. 1992;Journal:1040-1042. UI 1470112. [pmid: 1470112].
Harris J, May J. Comparison between saphenous vein and Dacron Velour grafts for femoropopliteal bypass. Australian & New Zealand Journal of Surgery. 1979;49:211-114. UI 157125. [pmid: 157125].
Harris PL, Campbell H. Femoro-distal bypass for critical ischemia: is the use of prosthetic grafts justified?. Annals of Vascular Surgery. 1986;1:66-72. UI 3504692. [pmid: 3504692].
Harward TR, Ingegno MD, Carlton L, Flynn TC, Seeger JM. Limb-threatening ischemia due to multilevel arterial occlusive disease. Simultaneous or staged inflow/outflow revascularization. Annals of Surgery. 503(221):498-503. UI 7748031.
Holm J. Endarterectomy vs prosthetic grafting. Acta Chirurgica Scandinavica - Supplementum. 1985;529:59-61. UI 3868902. [pmid: 3868902].
Hunink MG, Cullen KA, Donaldson MC. Hospital costs of revascularization procedures for femoropopliteal arterial disease. Journal of Vascular Surgery. 1994;19:632-641. UI 8164278. [pmid: 8164278].
Hurley JJ, Auer AI, Binnington HB, Hershey FB, Swensson EE, Woods JJ Jr. Comparison of initial limb salvage in 98 consecutive patients with either reversed autogenous or in situ vein bypass graft procedures. American Journal of Surgery. 1985;150:777-781. UI 4073372. [pmid: 4073372].
Hynes N, Akhtar Y, Manning B, Aremu M, Oiakhinan K, Courtney D, et al. Subintimal angioplasty as a primary modality in the management of critical limb ischemia: comparison to bypass grafting for aortoiliac and femoropopliteal occlusive disease. Journal of Endo vascular Therapy: Official Journal of the International Society of Endo vascular Specialists. 2004;11:460-471. UI 15298498.
Jackson MR, Ali AT, Bell C, Modrall JG, Welborn MB III, Scoggins E, et al. Aortofemoral bypass in young patients with premature atherosclerosis: is superficial femoral vein superior to Dacron?. Journal of Vascular Surgery. 2004;40:17-23. UI 15218456. [pmid: 15218456].
Jacobs MJ, Reul GJ, Gregoric ID, Ubbink DT, Tordoir JH, Kitslaar PJ, et al. Creation of a distal arteriovenous fistula improves microcirculatory hemodynamics of prosthetic graft bypass in secondary limb salvage procedures. Journal of Vascular Surgery. 1993;18:1-8. UI 8326649. [pmid: 8326649].
Karacagil S, Holmberg A, Narbani A, Eriksson I, Bergqvist D. Composite polytetrafluroethylene/vein bypass grafts: conventional distal vein segment or vein cuff?. European Journal of Vascular & Endovascular Surgery. 1996;12:337-341. UI 8896477. [pmid: 8896477].
Karanjia ND, Loosemore TM, Ray SA, Buckenham TM, Taylor RS, Dormandy JA. The differences in early haemodynamic response between surgery and angioplasty after successful reopening of the superficial femoral artery. European Journal of Vascular Surgery. 1993;7:717-719. UI 8270078. [pmid: 8270078].
Katz SGKR. Does dextran 40 improve the early patency of autogenous infrainguinal bypass grafts?. Journal of vascular surgery : official publication, the Society for Vascular Surgery [and] International Society for Cardiovascular Surgery, North American Chapter. 23-26. UI 9685127.
Kelly JJ, Kercher KW, Gallagher KA, Litwin DE, Arous EJ. Hand-assisted laparoscopic aortobifemoral bypass versus open bypass for occlusive disease. Journal of Laparoendoscopic & Advanced Surgical Techniques. 2002;Part:339-343. UI 12470408. [pmid: 12470408].
Kersting S, Ockert D, Zimmermann T, Meichelbock W, Saeger HD, Bergert H. Infragenicular polytetrafluoroethylene bypass with tapered versus straight vascular grafts: results from a prospective multicenter cohort study. Annals of Vascular Surgery. 2004;18:440-447. UI 15164262. [pmid: 15164262].
Killewich LA, Bartlett ST. The "all-autogenous" tissue policy for infrainguinal reconstruction questioned. American Journal of Surgery. 554(160):552-554. UI 2252111.
Klem TM, van der Ham AC, de Smet AA, Hok OI, Wittens CH. Hand assisted laparoscopic surgery of aortoiliac occlusive disease: initial results. European Journal of Vascular & Endovascular Surgery. 2006;32:639-644. UI 16863697. [pmid: 16863697].
Klevsgard R, Hallberg IR, Risberg B, Thomsen MB. The effects of successful intervention on quality of life in patients with varying degrees of lower-limb ischaemia. European Journal of Vascular & Endovascular Surgery. 2000;19:238-245. UI 10753686. [pmid: 10753686].
Kobayashi M, Hida K, Shikata H, Sakamoto S, Matsubara J. Long term outcome of femoropopliteal bypass for claudication and critical ischemia. Asian Cardiovascular & Thoracic Annals. 2004;12:208-212. UI 15353457. [pmid: 15353457].
Kotb MM, Kadir S, Bennett JD, Beam CA. Aortoiliac angioplasty: is there a need for other types of percutaneous intervention?. Journal of Vascular & Interventional Radiology. 1992;3:67-71. UI 1531773. [pmid: 1531773].
Kouchoukos NT, Levy JF, Balfour JF, Butcher HR Jr. Operative therapy for femoral-popliteal arterial occlusive disease. A comparison of therapeutic methods. Circulation. 1967;35. Suppl-82. UI 6024026.
Kreienberg PB, Darling RC III, Chang BB, Paty PS, Lloyd WE, Shah DM. Adjunctive techniques to improve patency of distal prosthetic bypass grafts: polytetrafluoroethylene with remote arteriovenous fistulae versus vein cuffs. Journal of Vascular Surgery. 2000;31:696-701. UI 10753277. [pmid: 10753277].
Kudo T, Chandra FA, Ahn SS. Long-term outcomes and predictors of iliac angioplasty with selective stenting. Journal of Vascular Surgery. 2005;42:466-475. UI 16171589. [pmid: 16171589].
Kwasnik EM, Siouffi SY, Jay ME, Khuri SF. Comparative results of angioplasty and aortofemoral bypass in patients with symptomatic iliac disease. Archives of Surgery. 1987;122:288-291. UI 2950842. [pmid: 2950842].
Lam EY, Landry GJ, Edwards JM, Yeager RA, Taylor LM, Moneta GL. Risk factors for autogenous infrainguinal bypass occlusion in patients with prosthetic inflow grafts. Journal of Vascular Surgery. 2004;39:336-342. UI 14743133. [pmid: 14743133].
Lam EY, Taylor LM Jr, Landry GJ, Porter JM, Moneta GL. Relationship between antiphospholipid antibodies and progression of lower extremity arterial occlusive disease after lower extremity bypass operations. Journal of Vascular Surgery. 2001;33:976-982. UI 11331837. [pmid: 11331837].
Lau H, Cheng SW. Is the preferential use of ePTFE grafts in femorofemoral bypass justified?. Annals of Vascular Surgery. 2001;15:383-387. UI 11414091. [pmid: 11414091].
Lazarides MK, Tzilalis VD, Georgiadis GS, Georgopoulos SE, Arvanitis DP. Femoral-anterior tibial reconstructions using cuffed PTFE grafts: routing alternatives. Vasa. 2003;32:22-25. UI 12677761. [pmid: 12677761].
Lazaro T, Gesto R, Fernandez V I, Fonseca JL, Lozano P, Porto J. Direct surgery on the aorto-iliac area. Prostheses--endarterectomy? International Surgery. 1988;73:213-217. UI 3251880. [pmid: 3251880].
Ljungman C, Ulus AT, Almgren B, Bergstrom R, Hellberg A, Bergqvist D, et al. A multivariate analysis of factors affecting patency of femoropopliteal and femorodistal bypass grafting. Vasa. 2000;29:215-220. UI 11037721. [pmid: 11037721].
Luk'ianov I, Sedov VM, Lebedev LV, Shlomin VV, Kas'ianov IV, Batalin IV, et al. [The efficacy of antithrombotic therapy after total obliteration-reversing therapy in atherosclerotic arterial occlusion of the lower extremities]. [Russian]. Vestnik Khirurgii Imeni i - i -Grekova. 1997;156:62-65. UI 9163197. [pmid: 9163197].
Lundgren F, Dahllof AG, Lundholm K, Schersten T, Volkmann R. Intermittent claudication--surgical reconstruction or physical training? A prospective randomized trial of treatment efficiency. Annals of Surgery. 1989;209:346-355. UI 2647051. [pmid: 2647051].
Madiba TE, Mars M, Robbs JV. Choosing the proximal anastomosis in aortobifemoral bypass. British Journal of Surgery. 1997;84:1416-1418. UI 9361602. [pmid: 9361602].
Magnant JG, Cronenwett JL, Walsh DB, Schneider JR, Besso SR, Zwolak RM. Surgical treatment of infrainguinal arterial occlusive disease in women. Journal of Vascular Surgery. 1976;17:67-76. UI 8421343. [pmid: 8421343].
Mares M, Sogaro F, Scomparin MA, Boeri G, Cella G. Effect of buflomedil, dipyridamole and indobufene on hemorrheologic and blood coagulation parameters in patients who underwent vascular surgery for severe atherosclerosis. Journal of Medicine. 1991;22:163-169. UI 1770324. [pmid: 1770324].
Markovi DM, Davidovi LB, Lotina SI, Kosti DM, Cinara IS, Svetkovi SD, et al. [Long-term patency of reversed and in situ femoro-popliteal bypasses]. [Serbian]. Srpski Arhiv Za Celokupno Lekarstvo. 1999;127:365-370. UI 10686817. [pmid: 10686817].
Martin EC, Fankuchen El, Karlson KB, Dolgin C, Collins RH, Voorhees AB Jr, et al. Angioplasty for femoral artery occlusion: comparison with surgery. AJR. 1981;American:915-919. UI 6457522. [pmid: 6457522].
Maspes F, Innocenzi L, Ascoli MA, Cossu E, Squillaci E, Pistolese GR, et al. [Percutaneous transluminal angioplasty in the treatment of iliac stenosis. The authors' new guideline for 100 patients]. [Italian]. Radiologia Medica. 1995;90:772-780. UI 8685462. [pmid: 8685462].
Melliere D, Desgranges P, de Wailly GW, Roudot-Thoraval F, Allaire E, Becquemin JP. Extensive unilateral iliofemoral occlusions: durability of four techniques of arterial reconstructions. Vascular. 2004;12:285-292. UI 15765909. [pmid: 15765909].
Mingoli A, Sapienza P, Feldhaus RJ, Di ML, Burchi C, Cavallaro A. Comparison of femorofemoral and aortofemoral bypass for aortoiliac occlusive disease. Journal of Cardiovascular Surgery. 2001;42:381-387. UI 11398037. [pmid: 11398037].
Misare BD, Pomposelli FB Jr, Gibbons GW, Campbell DR, Freeman DV, LoGerfo FW. Infrapopliteal bypasses to severely calcified, unclampable outflow arteries: two-year results. Journal of Vascular Surgery. 1996;24:6-15. UI 8691529. [pmid: 8691529].
Mohan CR, Sharp WJ, Hoballah JJ, Kresowik TF, Schueppert MT, Corson JD. A comparative evaluation of externally supported polytetrafluoroethylene axillobifemoral and axillounifemoral bypass grafts. Journal of Vascular Surgery. 808(21):801-808. UI 7769738.
Mohr R, Smolinsky A, Morag B, Bass A, Rubinstein ZJ, Adar R. Cardiac complications in vascular procedures: comparison of percutaneous angioplasty and surgery. Catheterization & Cardiovascular Diagnosis. 1983;9:339-343. UI 6226360. [pmid: 6226360].
Natali J, Lavarde G, Vinardi G. [Restorative arterial surgery in the ischemias caused by atheromatous obliteration of the femoro-popliteal axis. Comparative results of thrombo-endarterectomy and venous by-pass]. [French]. Journal de Chirurgie. 1968;96:145-167. UI 5702057. [pmid: 5702057].
Nazzal MM, Hoballah JJ, Jacobovicz C, Mohan CR, Martinasevic M, Ryan SM, et al. A comparative evaluation of femorofemoral crossover bypass and iliofemoral bypass for unilateral iliac artery occlusive disease. Angiology. 1998;49:259-265. UI 9555928. [pmid: 9555928].
Neugodov I. [Arteriovenous fistula in the reconstructive surgery of the femoral-popliteal-tibial segments]. [Russian]. Khirurgiia. 1990:28-33. UI 2292850. [pmid: 2292850].
Nypaver TJ, Ellenby MI, Mendoza O, Meyer JP, Schwarcz TH, Baraniewski H, et al. A comparison of operative approaches and parameters predictive of success in multilevel arterial occlusive disease. Journal of the American College of Surgeons. 1994;179:449-456. UI 7921396. [pmid: 7921396].
O'Donnell TF Jr, Farber SP, Richmand DM, Deterling RA, Callow AD. Above-knee polytetrafluoroethylene femoropopliteal bypass graft: Is it a reasonable alternative to the below-knee reversed autogenous vein graft?. Surgery. 1983;94:26-31. UI 15714367. [pmid: 6857508].
Oderich GS, Panneton JM, Yagubyan M, Bower TC, Hofer J, Noel AA, et al. Comparison of precuffed and vein-cuffed expanded polytetrafluoroethylene grafts for infragenicular arterial reconstructions: a case-matched study. Annals of Vascular Surgery. 2005;19:49-55. UI 6857508. [pmid: 15714367].
Ohtake H, Urayama H, Kimura K, Yokoi K, Tsunezuka Y, Kawakami T, et al. Comparison of cilostazol with warfarin as antithrombotic therapy after femoro-popliteal bypass surgery using an ePTFE graft. Minerva Cardioangiologica. 1997;45:527-530. UI 9549283. [pmid: 9549283].
Okadome K, Eguchi H, Yukizane T, Muto Y, Shimada M, Sugimachi K. Long-term results of arterial reconstruction of lower extremities determined by flow waveform analysis. Journal of Cardiovascular Surgery. 1989;30:64-69. UI 2522453. [pmid: 2522453].
Onohara T, Komori K, Kume M, Ishida M, Ohta S, Takeuchi K, et al. Multivariate analysis of long-term results after an axillobifemoral and aortobifemoral bypass in patients with aortoiliac occlusive disease. Journal of Cardiovascular Surgery. 2000;41:905-910. UI 11232974. [pmid: 11232974].
Owens CD, Ridker PM, Belkin M, Hamdan AD, Pomposelli F, Logerfo F, et al. Elevated C-reactive protein levels are associated with postoperative events in patients undergoing lower extremity vein bypass surgery. Journal of Vascular Surgery. 1909;45:2-9. UI 17123769. [pmid: 17123769].
Parmar JH, Aslam M, Standfield NJ. Peripheral arterial revascularization causing parallel increased activity of pro- and anti-inflammatory mediators. International Angiology. 2007;26:8-11. UI 17353882. [pmid: 17353882].
Pell JP, Lee AJ. Impact of angioplasty and arterial reconstructive surgery on the quality of life of claudicants. The Scottish Vascular Audit Group. Scottish Medical Journal. 1997;42:47-48. UI 9507581. [pmid: 9507581].
Piano G, Schwartz LB, Foster L, Bassiouny HS, McKinsey JF, Rosenthal D, et al. Assessing outcomes, costs, and benefits of emerging technology for minimally invasive saphenous vein in situ distal arterial bypasses. Archives of Surgery. 617(133):613-617. UI 9637459.
Pilger E, Decrinis M, Stark G, Koch G, Obernosterer A, Tischler R, et al. Thrombolytic treatment and balloon angioplasty in chronic occlusion of the aortic bifurcation. Annals of Internal Medicine. 1994;120:40-44. UI 8250455. [pmid: 8250455].
Proia RR, Walsh DB, Nelson PR, Connors JP, Powell RJ, Zwolak RM, et al. Early results of infragenicular revascularization based solely on duplex arteriography. Journal of Vascular Surgery. 2001;33:1165-1170. UI 11389413. [pmid: 11389413].
Pullatt R, Brothers TE, Robison JG, Elliott BM. Compromised bypass graft outcomes after minimal-incision vein harvest. Journal of Vascular Surgery. 294(44):289-294. UI 16890856.
Qian S, Iwai T, Sato S, Endo M. Evaluation of the measurement of the intraoperative transcutaneous partial pressure of oxygen (PtcO2) as a prognostic indicator in vascular reconstruction. Surgery Today. 1992;22:523-529. UI 1472792. [pmid: 1472792].
Quigley FG, Ling J, Avramovic J. Impact of femoro-distal bypass on major lower limb amputation rate. Australian & New Zealand Journal of Surgery. 1998;68:35-37. UI 9440453. [pmid: 9440453].
Reichle FA, Tyson RR. Bypasses to tibial or popliteal arteries in severely ischemic lower extremities: comparison of long-term results in 233 patients. Annals of Surgery. 1972;176:315-320. UI 126669. [pmid: 5073219].
Reichle FA, Tyson RR. Comparison of long-term results of 364 femoropopliteal or femorotibial bypasses for revascularization of severely ischemic lower extremities. Annals of Surgery. 1975;182:449-455. UI 5073219. [pmid: 126669].
Rendl KH. [Critical evaluation of femoro-popliteal-crural in situ venous bypass--experiments on valve elimination and hemodynamics]. [German]. Vasa- Supplementum. 1991;31:1-48. UI 1876964. [pmid: 1876964].
Rendl KH, Premier K. [3 years' experience with intraoperative transluminal angioplasty--a retrospective study]. [German]. Langenbecks Archiv fur Chirurgie. 1983;360:295-301. UI 6229677. [pmid: 6229677].
Rosenthal D, Arous EJ, Friedman SG, Ingegno MD, Johnson BL, Kraiss LW, et al. Endovascular-assisted versus conventional in situ saphenous vein bypass grafting: cumulative patency, limb salvage, and cost results in a 39-month multicenter study. Journal of Vascular Surgery. 2000;31:t-8. UI 10642709.
Rosenthal D, Mittenthal MJ, Ruben DM, Jones DH, Estes JW, Stanton PE Jr, et al. The effects of aspirin, dipyridamole and warfarin in femorodistal reconstruction: long-term results. American Surgeon. 1987;53:477-481. UI 3631756. [pmid: 3631756].
Rouers A, Meurisse N, Lavigne JP, Francart D, Quaniers J, Desiron Q, et al. Potential benefits of laparoscopic aorto-bifemoral bypass surgery. Acta Chirurgica Belgica. 2005;105:610-615. UI 16438070. [pmid: 16438070].
Sala F, Hassen-Khodja R, Lecis A, Bouillanne PJ, Declemy S, Batt M. Long-term outcome of femoral above-knee popliteal artery bypass using autologous saphenous vein versus expanded polytetrafluoroethylene grafts. Annals of Vascular Surgery. 2003;17:401-407. UI 14670018. [pmid: 14670018].
Sarcina A, Carlesi R, Bellosta R, Agrifoglio G. In situ saphenous vein bypass for limb salvage. Cardiovascular Surgery. 1993;1:33-37. UI 8075993. [pmid: 8075993].
Schlosser V, Herdter F, Spillner G, Ahmadi A. [New transplantation materials for reconstructive arterial surgery]. [German]. Fortschritte der Medizin. 1977;95:1012-1017. UI 558141. [pmid: 558141].
Schneider JR, Besso SR, Walsh DB, Zwolak RM, Cronenwett JL. Femorofemoral versus aortobifemoral bypass: outcome and hemodynamic results. Journal of Vascular Surgery. 1955;19:43-55. UI 8301737. [pmid: 8301737].
Schneider JR, Walsh DB, McDaniel MD, Zwolak RM, Besso SR, Cronenwett JL. Pedal bypass versus tibial bypass with autogenous vein: a comparison of outcome and hemodynamic results. Journal of Vascular Surgery. 1038;17:1029-1038. UI 8505781. [pmid: 8505781].
Schneider PA, Abcarian PW, Ogawa DY, Leduc JR, Wright PW. Should balloon angioplasty and stents have any role in operative intervention for lower extremity ischemia?. Annals of Vascular Surgery. 1997;11:574-580. UI 9363302. [pmid: 9363302].
Schneider PA, Caps MT, Ogawa DY, Hayman ES. Intraoperative superficial femoral artery balloon angioplasty and popliteal to distal bypass graft: an option for combined open and endovascular treatment of diabetic gangrene. Journal of Vascular Surgery. 2001;33:955-962. UI 11331834. [pmid: 11331834].
Schwierz T, Gschwendtner M, Havlicek W, Schmoeller F, Boehmig HJ, Fugger R. Indications for directed thrombolysis or new bypass in treatment of occlusion of lower extremity arterial bypass reconstruction. Annals of Vascular Surgery. 2001;15:644-652. UI 11769145. [pmid: 11769145].
Sciannameo F, Ronca P, Caselli M, Alberti D. [Surgery vs PTA in sub-inguinal atherosclerosis]. [Italian]. Minerva Cardioangiologica. 1993;41:123-128. UI 8332267. [pmid: 8332267].
Simonetti G, Urigo F, Guazzaroni M, Biglioli P, Dettori G, Bacciu PP. Iliac artery lesions: a comparison between percutaneous transluminal angioplasty and surgery. Annales de Radiologie. 1986;29:127-129. UI 2943205. [pmid: 2943205].
Simsir SA, Cabellon A, Kohlman-Trigoboff D, Smith BM. Factors influencing limb salvage and survival after amputation and revascularization in patients with end-stage renal disease. American Journal of Surgery. 1995;170:l13-117. UI 7631913.
Singh N, Sidawy AN, Dezee K, Neville RF, Weiswasser J, Arora S, et al. The effects of the type of anesthesia on outcomes of lower extremity infrainguinal bypass. Journal of Vascular Surgery. 968(44):964-968. UI 17000075.
Stipa S, Wheelock FC Jr. A comparison of femoral artery grafts in diabetic and nondiabetic patients. American Journal of Surgery. 1971;121:223-228. UI 5546325. [pmid: 5546325].
Storen G, Solheim K, Birkeland S. Reconstructive arterial surgery in peripheral obliterative atherosclerosis. Acta Chirurgica Scandinavica. 1975;141:619-623. UI 1211032. [pmid: 1211032].
Suggs WD, Sanchez LA, Woo D, Lipsitz EC, Ohki T, Veith FJ. Endoscopically assisted in situ lower extremity bypass graft: a preliminary report of a new minimally invasive technique. Journal of Vascular Surgery. 2001;34:668-672. UI 11668322. [pmid: 11668322].
Szabo GV, Laczko A, Szeberin Z, Windisch M, Szazados M, Kristof V, et al. [Anatomical and extra-anatomical reconstructions in aorto-iliac occlusive diseases]. [Hungarian]. Magyar Sebeszet. 2001;54. Suppl-2. UI 11816150.
Taylor SM, Kalbaugh CA, Blackhurst DW, Kellicut DC, Langan EM III, Youkey JR. A comparison of percutaneous transluminal angioplasty versus amputation for critical limb ischemia in patients unsuitable for open surgery. Journal of Vascular Surgery. 310(45):304-310. UI 17264008.
Thalhammer A, Balzer J, Jacobi V, Vogl T. [Stents in the iliac arteries: a minimally invasive method]. [German]. Hamostaseologie. 2003;23:67-70. UI 12736701. [pmid: 12736701].
Thompson JF, McShane MD, Gazzard V, Clifford PC, Chant AD. Limitations of percutaneous transluminal angioplasty in the treatment of femoro-distal graft stenoses. European Journal of Vascular Surgery. 1989;3:209-211. UI 2526024. [pmid: 2526024].
Thompson MM, Sayers RD, Reid A, Underwood MJ, Bell PR. Quality of life following infragenicular bypass and lower limb amputation. European Journal of Vascular & Endovascular Surgery. 1995;9:310-313. UI 7620957. [pmid: 7620957].
Timaran CH, Ohki T, Gargiulo NJ III, Veith FJ, Stevens SL, Freeman MB, et al. Iliac artery stenting in patients with poor distal runoff: Influence of concomitant infrainguinal arterial reconstruction. Journal of Vascular Surgery. 484(38):479-484. UI 12947261.
Timaran CH, Prault TL, Stevens SL, Freeman MB, Goldman MH. Iliac artery stenting versus surgical reconstruction for TASC (TransAtlantic Inter-Society Consensus) type B and type C iliac lesions. Journal of Vascular Surgery. 2003;38:272-278. UI 12891108. [pmid: 12891108].
Townley WA, Carrell TW, Jenkins MP, Wolfe JH, Cheshire NJ. Critical limb ischemia in the dialysis-dependent patient: infrainguinal vein bypass is justified. Vascular & Endovascular Surgery. 2006;40:362-366. UI 17038569. [pmid: 17038569].
Urayama H, Ohtake H, Yokoi K, Fujimori H, Kawaguchi M, Ishikawa T, et al. Long-term results of endarterectomy, anatomic bypass and extraanatomic bypass for aortoiliac occlusive disease. Surgery Today. 1998;28:151-155. UI 9525003. [pmid: 9525003].
van den Akker PJ, van SR, Brand R, Hajo van BJ, Terpstra JL. Long-term results of prosthetic and non-prosthetic reconstruction for obstructive aorto-iliac disease. European Journal of Vascular Surgery. 1992;6:53-61. UI 1555671. [pmid: 1555671].
van LD, Kuijpers PJ, Skotnicki SH, Meyer I. Aorto-iliac surgery: a comparative study between thrombo-endarterectomy and bypass. Journal of Cardiovascular Surgery. 1974;15:352-355. UI 4841939. [pmid: 4841939].
Vanttinen E, Inberg MV. Aorto-ilicofemoral arterial reconstructive surgery. With special reference to profunda revascularization. Acta Chirurgica Scandinavica. 1975;141:600-608. UI 1211030. [pmid: 1211030].
Vukobratov V, Kaanski M, Pasternak J, Nikoli D, Popovi V, Obradovi J. [Femoro-popliteal reconstructions: "in situ" versus "reversed" technique: comparative results]. [Serbian]. Medicinski Pregled. 2006;59:360-364. UI 17140037. [pmid: 17140037].
Vukobratov V, Pasternak J, Obradovi J, Kaanski M, Popovi V, Nikoli D. [Results of auto venous femoro-distal bypass procedures in the type III peripheral obliterative arterial disease of the extremities in diabetic and nondiabetic patients]. [Serbian]. Medicinski Pregled. 2006;59:472-475. UI 17345825. [pmid: 17345825].
Wagner W, Bartel M, Clausner G, Schleicher C. [Long-term results following femoro-popliteal vascular reconstruction]. [German]. Zentralblatt fur Chirurgie. 1989;114:157-168. UI 2711785. [pmid: 2711785].
Weinstein MH, Machleder HI. Sexual function after aorto-lliac surgery. Annals of Surgery. 1975;181:787-790. UI 1138627. [pmid: 1138627].
Whatling PJ, Gibson M, Torrie EP, Magee TR, Galland RB. Iliac occlusions: stenting or crossover grafting? An examination of patency and cost. European Journal of Vascular & Endovascular Surgery. 2000;20:36-40. UI 10906295. [pmid: 10906295].
Whittemore AD. Autogenous saphenous vein versus PTFE bypass for above-knee femoropopliteal reconstruction. Journal of Vascular Surgery. 1992;15:895-897. UI 1578557. [pmid: 1578557].
Wolfle KD, Bruijnen H, Loeprecht H, Rumenapf G, Schweiger H, Grabitz K, et al. Graft patency and clinical outcome of femorodistal arterial reconstruction in diabetic and non-diabetic patients: results of a multicentre comparative analysis. European Journal of Vascular & Endovascular Surgery. 2003;25:229-234. UI 12623334. [pmid: 12623334].
Yoshitomi Y, Kojima S, Umemoto T, Hosoi Y, Kuramochi M. A retrospective study of late outcome in patients with peripheral arterial occlusive disease: an association between prosthetic vascular graft and cancer death?. Angiology. 1999;50:1007-1015. UI 10609767. [pmid: 10609767].
Zan S, Varetto G, Maselli M, Conforti M, Moniaci D, Scovazzi P. [Therapeutic approach to the unilateral occlusive iliac artery disease. Preliminary results]. [Italian]. Minerva Cardioangiologica. 2003;51:71-77. UI 12652263. [pmid: 12652263].

## Case control studies that evaluate bypass

Galland RB, Whiteley MS, Gibson M, Simmons MJ, Torrie EP, Magee TR. Maintenance of patency following remote superficial femoral artery endarterectomy. Cardiovascular Surgery. 2000;8:533-537. UI 11068213. [pmid: 11068213].
Ohnishi K, Kato M, Ohtani M, Imagawa H, Takano H, Yoshioka Y. [Comparison of long-term patency rates of transluminal angioplasty and bypass grafting]. [Japanese]. Nippon Geka Gakkai Zasshi. 1992;Journal:1049-1051. UI 1470115. [pmid: 1470115].
Reddan DN, Marcus RJ, Owen WF Jr, Szczech LA, Landwehr DM. Long-term outcomes of revascularization for peripheral vascular disease in end-stage renal disease patients. American Journal of Kidney Diseases. 2001;38:57-63. UI 11431182. [pmid: 11431182].

## RCTs that evaluate atherectomy

Gaspard DJ, Cohen JL, Gaspar MR. Aortoiliofemoral thromboendarterectomy vs bypass graft. A randomized study. Archives of Surgery. 1972;105:898-901. UI 4264387. [pmid: 4264387].
Gordon IL, Conroy RM, Tobis JM, Kohl C, Wilson SE. Determinants of patency after percutaneous angioplasty and atherectomy of occluded superficial femoral arteries. American Journal of Surgery. 1994;168:115-119. UI 8053507. [pmid: 8053507].
Nakamura S, Conroy RM, Gordon IL, Deutsch LS, Maheswaran B, Antone CS, et al. A randomized trial of transcutaneous extraction atherectomy in femoral arteries: intravascular ultrasound observations. Journal of Clinical Ultrasound. 1995;23:461-471. UI 7499516. [pmid: 7499516].
Tielbeek AV, Vroegindeweij D, Buth J, Landman GH. Comparison of balloon angioplasty and Simpson atherectomy for lesions in the femoropopliteal artery: angiographic and clinical results of a prospective randomized trial. Journal of Vascular & Interventional Radiology. 1996;7:837-844. UI 8951750. [pmid: 8951750].
van derZaag ES, Prins MH, Jacobs MJ. [Treatment of intermittent claudication; prospective randomized study in the BAESIC-Trial (bypass, angioplasty or endarterectomy patients with severe intermittent claudication)]. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1996;140:787-788. UI 8668267. [pmid: 8668267].
Vroegindeweij D, Kemper FJ, Tielbeek AV, Buth J, Landman G. Recurrence of stenoses following balloon angioplasty and Simpson atherectomy of the femoro-popliteal segment. A randomised comparative 1-year follow-up study using colour flow duplex. European Journal of Vascular Surgery. 1992;6:164-171. UI 1533372. [pmid: 1533372].
Vroegindeweij D, Tielbeek AV, Buth J, Schol FP, Hop WC, Landman GH. Directional atherectomy versus balloon angioplasty in segmental femoropopliteal artery disease: two-year follow-up with color-flow duplex scanning. Journal of Vascular Surgery. 268(21):255-268. UI 7853599.

## Nonrandomized comparative studies that evaluate atherectomy

Caparoski R, Kaftandziev D, Colanceski V, Vitanov A, Dimitrov V, Savevski J, et al. [Results of reconstructive bypass surgery of obliterative arteriosclerosis in the aortoiliac segment]. [Croatian]. Acta Chirurgica Iugoslavica. 1978;25:199-202. UI 654762. [pmid: 654762].
Courchia G, Serise JM, Moreau JL, Delorge C, Winnock S, Boissieras P. [Peroperative angiography in reparative surgery of the lower limbs. Apropos of experience with 1099 cases]. [French]. Journal des Maladies Vasculaires. 1988;13:11-19. UI 2964494. [pmid: 2964494].
Crew JR, Thuener M. Wound Healing: An endpoint for complex peripheral angioplasty. Journal of Endovascular Surgery. 1994;1:88-91. UI 9234109. [pmid: 9234109].
d'Othee BJ, Langdon DR, Bell GK, Bettmann MA. Operating expenses for the diagnosis and treatment of peripheral vascular disease in an academic interventional radiology department: cost calculations according to a microeconomic method. Journal of Vascular & Interventional Radiology. 2006;17:85-94. UI 5013767. [pmid: 16415137].
Darling RC, Linton RR. Durability of femoropopliteal reconstructions. Endarterectomy versus vein bypass grafts. American Journal of Surgery. 1972;123:472-479. UI 16415137. [pmid: 5013767].
Duncan WC, Linton RR, Darling RC. Aortoiliofemoral atherosclerotic occlusive disease: comparative results of endarterectomy and Dacron bypass grafts. Surgery. 1971;70:974-984. UI 5124676. [pmid: 5124676].
Fernandes e Fernandes, Nicolaides AN, Angelides NA, Gordon-Smith IC. An objective assessment of common femoral endarterectomy and profundaplasty in patients with superficial femoral occlusion. Surgery. 1978;83:313-318. UI 628894. [pmid: 628894].
Holm J. Endarterectomy vs prosthetic grafting. Acta Chirurgica Scandinavica - Supplementum. 1985;529:59-61. UI 3868902. [pmid: 3868902].
Kotb MM, Kadir S, Bennett JD, Beam CA. Aortoiliac angioplasty: is there a need for other types of percutaneous intervention?. Journal of Vascular & Interventional Radiology. 1992;3:67-71. UI 1531773. [pmid: 1531773].
Kreienberg PB, Darling RC III, Chang BB, Paty PS, Lloyd WE, Shah DM. Adjunctive techniques to improve patency of distal prosthetic bypass grafts: polytetrafluoroethylene with remote arteriovenous fistulae versus vein cuffs. Journal of Vascular Surgery. 2000;31:696-701. UI 10753277. [pmid: 10753277].
Lazaro T, Gesto R, Fernandez V I, Fonseca JL, Lozano P, Porto J. Direct surgery on the aorto-iliac area. Prostheses--endarterectomy? International Surgery. 1988;73:213-217. UI 3251880. [pmid: 3251880].
Melliere D, Desgranges P, de Wailly GW, Roudot-Thoraval F, Allaire E, Becquemin JP. Extensive unilateral iliofemoral occlusions: durability of four techniques of arterial reconstructions. Vascular. 2004;12:285-292. UI 15765909.
Natali J, Lavarde G, Vinardi G. [Restorative arterial surgery in the ischemias caused by atheromatous obliteration of the femoropopliteal axis. Comparative results of thrombo-endarterectomy and venous by-pass]. [French]. Journal de Chirurgie. 1968;96:145-167. UI 5702057. [pmid: 5702057].
Reid JD, Hsiang YN, Doyle DL, Sladen JG, Fry PD, Machan LS, et al. Atherectomy. Early use of three different methods. Canadian Journal of Surgery. 1992;35:242-245. UI 1535542.
Rendl KH, Prenner K. [3 years' experience with intraoperative transluminal angioplasty--a retrospective study]. [German]. Langenbecks Archiv fur Chirurgie. 1983;360:295-301. UI 6229677. [pmid: 6229677].
Sapienza P, Mingoli A, McGill JE, Perdikis G, Cavallari N, Feldhaus RJ. Comparative long-term results of laser-assisted balloon angioplasty and atherectomy in the treatment of peripheral vascular disease. American Journal of Surgery. 644(168):640-644. UI 7978011.
Storen G, Solheim K, Birkeland S. Reconstructive arterial surgery in peripheral obliterative atherosclerosis. Acta Chirurgica Scandinavica. 1975;141:619-623. UI 1211032. [pmid: 1211032].
Suy R, Daenen W, Pakdaman A, Stalpaert G. [Vascular surgery of femoro-popliteal axis. Compared results of thromboendarterectomy by venous overbridging and overbridging with dacron]. [French]. Angeiologie. 1970;22:63-74. UI 5420913. [pmid: 5420913].
Urayama H, Ohtake H, Yokoi K, Fujimori H, Kawaguchi M, Ishikawa T, et al. Long-term results of endarterectomy, anatomic bypass and extraanatomic bypass for aortoiliac occlusive disease. Surgery Today. 1998;28:151-155. UI 9525003. [pmid: 9525003].
van den Akker PJ, van SR, Brand R, Hajo van BJ, Terpstra JL. Long-term results of prosthetic and non-prosthetic reconstruction for obstructive aorto-iliac disease. European Journal of Vascular Surgery. 1992;6:53-61. UI 1555671. [pmid: 1555671].
van LD, Kuijpers PJ, Skotnicki SH, Meyer I. Aorto-iliac surgery: a comparative study between thrombo-endarterectomy and bypass. Journal of Cardiovascular Surgery. 1974;15:352-355. UI 4841939. [pmid: 4841939].
Vanttinen E, Inberg MV. Aorto-ilicofemoral arterial reconstructive surgery. With special reference to profunda revascularization. Acta Chirurgica Scandinavica. 1975;141:600-608. UI 1211030. [pmid: 1211030].
Vroegindeweij D, Idu M, Buth J, Nillesen C, Schol FP, Tielbeek AV. The cost-effectiveness of treatment of short occlusive lesions in the femoropopliteal artery: balloon angioplasty versus endarterectomy. European Journal of Vascular & Endo vascular Surgery. 1995;10:40-50. UI 7633969.
Wagner W, Bartel M, Clausner G, Schleicher C. [Long-term results following femoro-popliteal vascular reconstruction]. [German]. Zentralblatt fur Chirurgie. 1989;114:157-168. UI 2711785. [pmid: 2711785].
Weinstein MH, Machleder HI. Sexual function after aorto-iliac surgery. Annals of Surgery. 1975;181:787-790. UI 1138627. [pmid: 1138627].

## Case control studies that evaluate atherectomy

Galland RB, Whiteley MS, Gibson M, Simmons MJ, Torrie EP, Magee TR. Maintenance of patency following remote superficial femoral artery endarterectomy. Cardiovascular Surgery. 2000;8:533-537. UI 11068213. [pmid: 11068213].
Gusinski AV, Shlomin VV, Lebedev LV, Solov'ev AV, Iurtaev EA, Sharipov EM, et al. [Semiclosed endarterectomy of the aorto-femoral segment by Vollmar loops]. [Russian]. Vestnik Khirurgii Imeni i - i - Grekova. 2003;162:11-15. UI 12942602.

## Systematic Reviews

Albers M, Battistella VM, Romiti M, Rodrigues AA, Pereira CA. Meta-analysis of polytetrafluoroethylene bypass grafts to infrapopliteal arteries. Journal of Vascular Surgery. 2003;37:1263-1269. UI 12764274. [pmid: 12764274].
Albers M, Romiti M, Brochado-Neto FC, Pereira CA. Meta-analysis of alternate autologous vein bypass grafts to infrapopliteal arteries. Journal of Vascular Surgery. 2005;42:449-455. UI 16171586. [pmid: 16171586].
Albers M, Romiti M, De LN, Brochado-Neto FC, Nishimoto I, Pereira CA. An updated meta-analysis of infrainguinal arterial reconstruction in patients with end-stage renal disease. Journal of Vascular Surgery. 2007;45:536-542. UI 17257801. [pmid: 17257801].
Albers M, Romiti M, Pereira CA, Antonini M, Wulkan M. Meta-analysis of allograft bypass grafting to infrapopliteal arteries. European Journal of Vascular & Endovascular Surgery. 2004;28:462-472. UI 15465366. [pmid: 15465366].
Bachoo P, Thorpe P. Endovascular stents for intermittent claudication. Cochrane Database of Systematic Reviews. 2003:CD003228. UI 12535463. [pmid: 12535463].
Bosch JL, Hunink MG. Meta-analysis of the results of percutaneous transluminal angioplasty and stent placement for aortoiliac occlusive disease, [erratum appears in Radiology 1997 Nov; 205(2):584]. Radiology. 1997;204:87-96. UI 9205227. [pmid: 9205227].
Cassar K, Bachoo P, Brittenden J. The effect of peripheral percutaneous transluminal angioplasty on quality of life in patients with intermittent claudication. European Journal of Vascular & Endovascular Surgery. 2003;26:130-136. UI 12917825. [pmid: 12917825].
de Vries SO, Hunink MG. Results of aortic bifurcation grafts for aortoiliac occlusive disease: a meta-analysis. Journal of Vascular Surgery. 1997;26:558-569. UI 9357455. [pmid: 9357455].
Dick P, Mlekusch W, Sabeti S, Amighi J, Schlager O, Haumer M, et al. Outcome after endovascular treatment of deep femoral artery stenosis: results in a consecutive patient series and systematic review of the literature. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2006;13:221-228. UI 16643077.
Eskelinen E, Lepantalo M. Role of infrainguinal angioplasty in the treatment of critical limb ischaemia. Scandinavian Journal of Surgery: SJS. 2007;96:11-16. UI 17461306. [pmid: 17461306].
Fahner PJ, Idu MM, van Gulik TM, Legemate DA. Systematic review of preservation methods and clinical outcome of infrainguinal vascular allografts. Journal of Vascular Surgery. 2006;44:518-524. UI 16950428. [pmid: 16950428].
Hansrani M, Overbeck K, Smout J, Stansby G. Intravascular brachytherapy: a systematic review of its role in reducing restenosis after endovascular treatment in peripheral arterial disease. European Journal of Vascular & Endovascular Surgery. 2002;24:377-382. UI 12435336. [pmid: 12435336].
Hunink MG, Wong JB, Donaldson MC, Meyerovitz MF, Harrington DP. Patency results of percutaneous and surgical revascularization for femoropopliteal arterial disease. Medical Decision Making. 1994;14:71-81. UI 8152359. [pmid: 8152359].
Killeen SD, Andrews EJ, Redmond HP, Fulton GJ. Provider volume and outcomes for abdominal aortic aneurysm repair, carotid endarterectomy, and lower extremity revascularization procedures. Journal of Vascular Surgery. 2007;45:615-626. UI 17321352. [pmid: 17321352].
Klinkert P, Post PN, Breslau PJ, van Bockel JH. Saphenous vein versus PTFE for above-knee femoropopliteal bypass. A review of the literature. European Journal of Vascular & Endovascular Surgery. 2004;27:357-362. UI 15015183. [pmid: 15015183].
Lepantalo M, Eskelinen E. Outcome of infrapopliteal bypass in the elderly. Acta Chirurgica Belgica. 2007;107:1-7. UI 17405591. [pmid: 17405591].
Loftus IM, Hayes PD, Bell PR. Subintimal angioplasty in lower limb ischaemia. Journal of Cardiovascular Surgery. 2004;45:217-229. UI 15179334. [pmid: 15179334].
Mamode N, Scott RN. Graft type for femoro-popliteal bypass surgery. Cochrane Database of Systematic Reviews. 2000:CD001487. UI 10796649. [pmid: 10796649].
Mattes E, Norman PE, Jamrozik K. Falling incidence of amputations for peripheral occlusive arterial disease in Western Australia between 1980 and 1992. European Journal of Vascular & Endovascular Surgery. 1997;13:14-22. UI 9046909. [pmid: 9046909].
Mayfield JA, Caps MT, Reiber GE, Maynard C, Czerniecki JM, Sangeorzan BJ. Trends in peripheral vascular procedures in the Veterans Health Administration, 1989–1998. Journal of Rehabilitation Research & Development. 2001;38:347-356. UI 11440267. [pmid: 11440267].
Muradin GS, Bosch JL, Stijnen T, Hunink MG. Balloon dilation and stent implantation for treatment of femoropopliteal arterial disease: meta-analysis. Radiology. 2001;221:137-145. UI 11568332. [pmid: 11568332].
Nio D, Diks J, Bemelman WA, Wisselink W, Legemate DA. Laparoscopic vascular surgery: a systematic review. European Journal of Vascular & Endovascular Surgery. 2007;33:263-271. UI 17127084. [pmid: 17127084].
Paraskevas KI, Liapis CD, Hamilton G, Mikhailidis DP. Can statins reduce perioperative morbidity and mortality in patients undergoing non-cardiac vascular surgery?. European Journal of Vascular & Endovascular Surgery. 2006;32:286-293. UI 16690330. [pmid: 16690330].
Rocha-Singh KJ, Jaff MR, Crabtree TR, Bloch DA, Ansel G. VIVA Physicians I. Performance goals and endpoint assessments for clinical trials of femoropopliteal bare nitinol stents in patients with symptomatic peripheral arterial disease. Catheterization & Cardiovascular Interventions. 2007;69:910-919. UI 17377972. [pmid: 17377972].
Spronk S, Bosch JL, Veen HF, den Hoed PT, Hunink MG. Intermittent claudication: functional capacity and quality of life after exercise training or percutaneous transluminal angioplasty-- systematic review. Radiology. 2005;235:833-842. UI 15860674. [pmid: 15860674].
Takagi H, Sugimoto M, Kato T, Matsuno Y, Umemoto T. Postoperative incision hernia in patients with abdominal aortic aneurysm and aortoiliac occlusive disease: a systematic review. European Journal of Vascular & Endovascular Surgery. 2007;33:177-181. UI 16934501. [pmid: 16934501].