# Excluded Articles (and Reasons)

Abando A, Akopian G, Katz SG. Patient sex and success of peripheral percutaneous transluminal arterial angioplasty. Archives of Surgery. 2005. 16103285. Not stent vs other
Ansel GM, Silver MJ, Botti CF, Rocha-Singh K, Bates MC, Rosenfield K, Schainfeld RM, Laster SB, Zander C. Functional and clinical outcomes of nitinol stenting with and without abciximab for complex superficial femoral artery disease: a randomized trial. Catheterization & Cardiovascular Interventions. 2006. 16408299. Not stent vs other
Aoki J, Colombo A, Dudek D, Banning AP, Drzewiecki J, Zmudka K, Schiele F, Russell ME, Koglin J, Serruys PW. TAXUS II Study Group. Peri stent remodeling and neointimal suppression 2 years after polymer-based, paclitaxel-eluting stent implantation: insights from serial intravascular ultrasound analysis in the TAXUS II study. Circulation. 2005. 16344384. No clinical outcomes (st v other)
Ascher E, Marks NA, Hingorani AP, Schutzer RW, Mutyala M. Duplex-guided endovascular treatment for occlusive and stenotic lesions of the femoral-popliteal arterial segment: a comparative study in the first 253 cases. Journal of Vascular Surgery. 2006. 17055689. Not stent vs other
Ascher E, Marks NA, Schutzer RW, Hingorani AP. Duplex-guided balloon angioplasty and stenting for femoropopliteal arterial occlusive disease: an alternative in patients with renal insufficiency. Journal of Vascular Surgery. 2005. 16376200. Not stent vs other
Bauermeister G. Endovascular stent-grafting in the treatment of superficial femoral artery occlusive disease. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2001. 11491267. Not stent vs other
Beier F, Gyongyosi M, Raeder T, von Eckardstein-Thumb E, Sperker W, Albrecht P, Spes C, Glogar D, Mudra H. First inhuman randomized comparison of an anodized niobium stent versus a standard stainless steel stent-an intravascular ultrasound and angiographic two-center study: the VELA study. Clinical Research in Cardiology. 2006. 16799877. Not PAD
Benedek I. Interventional treatment with autoexpandable stents in iliofemoral arterial diseases. Romanian Journal of Internal Medicine. 2005. 16812983. Not stent vs other
Bonvini R, Baumgartner I, Do DD, Alerci M, Segatto JM, Tutta P, Jager K, Aschwanden M, Schneider E, mann-Vesti B, Greiner R, Mahler F, Gallino A. Late acute thrombotic occlusion after endovascular brachytherapy and stenting of femoropopliteal arteries. Journal of the American College of Cardiology. 2003. 12575967. Not stent vs other
Cambria RA, Farooq MM, Mewissen MW, Freischlag JA, Seabrook GR, Crain MR, Goldblatt MI, Paz-Fumagalli R, Towne JB. Endovascular therapy of iliac arteries: routine application of intraluminal stents does not improve clinical patency. Annals of Vascular Surgery. 1999. 10541614. Not stent vs other
Costanza MJ, Queral LA, Lilly MP, Finn WR. Hemodynamic outcome of endovascular therapy for TransAtlantic InterSociety Consensus type B femoropopliteal arterial occlusive lesions. Journal of Vascular Surgery. 2004. 14743134. No clinical outcomes (st v other)
Duda SH, Bosiers M, Lammer J, Scheinert D, Zeller T, Tielbeek A, Anderson J, Wiesinger B, Tepe G, Lansky A, Mudde C, Tielemans H, Beregi JP. Sirolimus-eluting versus bare nitinol stent for obstructive superficial femoral artery disease: the SIROCCO II trial. Journal of Vascular & Interventional Radiology. 2005. 15758128. Early subgroup of later publication
Duda SH, Pusich B, Richter G, Landwehr P, Oliva VL, Tielbeek A, Wiesinger B, Hak JB, Tielemans H, Ziemer G, Cristea E, Lansky A, Beregi JP. Sirolimus-eluting stents for the treatment of obstructive superficial femoral artery disease: six-month results. Circulation. 2002. 12234956. Early subgroup of later publication
Funovics MA, Lackner B, Cejna M, Peloschek P, Sailer J, Philipp MO, Maca T, Ahmadi A, Minar E, Lammer J. Predictors of long-term results after treatment of iliac artery obliteration by transluminal angioplasty and stent deployment. Cardiovascular & Interventional Radiology. 2002. 12447561. Not stent vs other
Galaria II, Davies MG. Percutaneous transluminal revascularization for iliac occlusive disease: long-term outcomes in TransAtlantic Inter-Society Consensus A and B lesions. Annals of Vascular Surgery. 2005. 15818461. No clinical outcomes (st v other)
Greenberg D, Rosenfield K, Garcia LA, Berezin RH, Lavelle T, Fogleman S, Cohen DJ. In-hospital costs of self-expanding nitinol stent implantation versus balloon angioplasty in the femoropopliteal artery (the VascuCoil Trial). Journal of Vascular & Interventional Radiology. 2004. 15466792. No original data
Hanekamp CE, Koolen JJ, den HP, Schalij MJ, Piek JJ, Bar FW, De S, Bonnier HJ, Pijls NH. Venestent Study Group. Randomized study to compare balloon angioplasty and elective stent implantation in venous bypass grafts: the Venestent study. Catheterization & Cardiovascular Interventions. 2003. 14624420. Graft lesion
Hassen-Khodja R, Sala F, Declemy S, Bouillanne PJ, Batt M, Staccini P. Value of stent placement during percutaneous transluminal angioplasty of the iliac arteries. Journal of Cardiovascular Surgery. 2001. 11398035. <80% stent arm actually had stent
Hausegger KA, Lammer J, Hagen B, Fluckiger F, Lafer M, Klein GE, Pilger E. Iliac artery stenting--clinical experience with the Palmaz stent, Wall stent, and Strecker stent. Acta Radiologica. 1992. 1633038. Not stent vs other
Henry M, Amor M, Ethevenot G, Henry I, Mentre B, Tzvetanov K. Percutaneous endoluminal treatment of iliac occlusions: long-term follow-up in 105 patients. Journal of Endovascular Surgery. 1998. 9761574. No clinical outcomes (st v other)
Kiesz RS, Buszman P, Martin JL, Deutsch E, Rozek MM, Gaszewska E, Rewicki M, Seweryniak P, Kosmider M, Tendera M. Local delivery of enoxaparin to decrease restenosis after stenting: results of initial multicenter trial: Polish-American Local Lovenox NIR Assessment study (The POLONIA study). Circulation. 2001. 11136681. Not PAD
Krajcer Z, Sioco G, Reynolds T. Comparison of Wallgraft and Wallstent for treatment of complex iliac artery stenosis and occlusion. Preliminary results of a prospective randomized study. Texas Heart Institute Journal. 1997. 9339507. N<10 per arm
Kruse JR, Cragg AH. Safety of short stay observation after peripheral vascular intervention. Journal of Vascular & Interventional Radiology. 2000. 10693712. Not stent vs other
Kudo T, Chandra FA, Ahn SS. The effectiveness of percutaneous transluminal angioplasty for the treatment of critical limb ischemia: a 10-year experience. Journal of Vascular Surgery. 435. 15838475. Not stent vs other
Kuribayashi S, Takamiya M, Homma S. Intravascular ultrasound observations during iliac stent deployment. International Angiology. 1999. 10811513. No clinical outcomes (st v other)
Long AL, Page PE, Raynaud AC, Beyssen BM, Fiessinger JN, Ducimetiere P, Relland JY, Gaux JC. Percutaneous iliac artery stent: angiographic long-term follow-up. Radiology. 1991. 1831274. Not stent vs other
Lopez-Galarza LA, Ray LI, Rodriguez-Lopez J, Diethrich EB. Combined percutaneous transluminal angioplasty, iliac stent deployment, and femorofemoral bypass for bilateral aortoiliac occlusive disease. Journal of the American College of Surgeons. 1997. 9060920. Not stent vs other
Lorenzi G, Domanin M, Costantini A, Rolli A, Agrifoglio G. Role of bypass, endarterectomy, extra-anatomic bypass and endovascular surgery in unilateral iliac occlusive disease: a review of 1257 cases. Cardiovascular Surgery. 1994. 8049976. <80% stent arm actually had stent
Madera FA, Orecchia PM, Razzino RA, Razzino J, Calcagno D. Balloon angioplasty by vascular surgeons. American Journal of Surgery. 1997. 9293833. Not stent vs other
Martin EC, Katzen BT, Benenati JF, Diethrich EB, Dorros G, Graor RA, Horton KM, Iannone LA, Isner JM, Ramee SR. Multicenter trial of the wallstent in the iliac and femoral arteries. Journal of Vascular & Interventional Radiology. 1995. 8850658. Not stent vs other
Mehilli J, Kastrati A, Wessely R, Dibra A, Hausleiter J, Jaschke B, Dirschinger J, Schomig A. Intracoronary Stenting and Angiographic Restenosis-. Randomized trial of a nonpolymer-based rapamycin-eluting stent versus a polymer-based paclitaxel-eluting stent for the reduction of late lumen loss. Circulation. 2006. 16391155. Not PAD
Minar E, Pokrajac B, Maca T, Ahmadi R, Fellner C, Mittlbock M, Seitz W, Wolfram R, Potter R. Endovascular brachytherapy for prophylaxis of restenosis after femoropopliteal angioplasty : results of a prospective randomized study. Circulation. 2000. 11094034. Not stent
Mousa A, Rhee JY, Trocciola SM, Dayal R, Beauford RB, Kumar N, Henderson P, McKinsey J, Morrissey NJ, Kent KC, Faries PL. Percutaneous endovascular treatment for chronic limb ischemia. Annals of Vascular Surgery. 2005. 15782274. Not stent vs other
Murphy TP, Khwaja AA, Webb MS. Aortoiliac stent placement in patients treated for intermittent claudication. Journal of Vascular & Interventional Radiology. 1998. 9618100. Not stent vs other
Ponec D, Jaff MR, Swischuk J, Feiring A, Laird J, Mehra M, Popma JJ, Donohoe D, Firth B, Keim E, Snead D, CRISP S. The Nitinol SMART stent vs Wall stent for suboptimal iliac artery angioplasty: CRISP-US trial results. Journal of Vascular & Interventional Radiology. 2004. 15361558. <80% had de novo treatment
Powell RJ, Fillinger M, Bettmann M, Jeffery R, Langdon D, Walsh DB, Zwolak R, Hines M, Cronenwett JL. The durability of endovascular treatment of multisegment iliac occlusive disease. Journal of Vascular Surgery. 2000. 10842155. Not stent vs other
Ryer EJ, Trocciola SM, DeRubertis B, Lam R, Hynecek RL, Karwowski J, Bush HL, Mureebe L, McKinsey JF, Morrissey NJ, Kent KC, Faries PL. Analysis of outcomes following failed endovascular treatment of chronic limb ischemia. Annals of Vascular Surgery. 2006. 16865606. Not stent vs other
Sabeti S, Schillinger M, Amighi J, Sherif C, Mlekusch W, Ahmadi R, Minar E. Primary patency of femoropopliteal arteries treated with nitinol versus stainless steel self-expanding stents: propensity score-adjusted analysis. Radiology. 2004. 15286322. No clinical outcomes (st v other)
Schillinger M, Exner M, Mlekusch W, Haumer M, Ahmadi R, Rumpold H, Wagner O, Minar E. Balloon angioplasty and stent implantation induce a vascular inflammatory reaction. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2002. 11958327. <1 mo no clinical outcomes
Schlager O, Dick P, Sabeti S, Amighi J, Mlekusch W, Minar E, Schillinger M. Long-segment SFA stenting--the dark sides: in-stent restenosis, clinical deterioration, and stent fractures. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2005. 16363897. Not stent vs other
Schneider PA, Abcarian PW, Ogawa DY, Leduc JR, Wright PW. Should balloon angioplasty and stents have any role in operative intervention for lower extremity ischemia?. Annals of Vascular Surgery. 1997. 9363302. Not stent vs other
Tanabe K, Serruys PW, Degertekin M, Guagliumi G, Grube E, Chan C, Munzel T, Belardi J, Ruzyllo W, Bilodeau L, Kelbaek H, Ormiston J, Dawkins K, Roy L, Strauss BH, Disco C, Koglin J, Russell ME, Colombo A. TAXUS II Study Group. Chronic arterial responses to polymer-controlled paclitaxel-eluting stents: comparison with bare metal stents by serial intravascular ultrasound analyses: data from the randomized TAXUS-II trial. Circulation. 2004. 14691036. No clinical outcomes (st v other)
Taylor SM, Kalbaugh CA, Blackhurst DW, Kellicut DC, Langan EM, Youkey JR. A comparison of percutaneous transluminal angioplasty versus amputation for critical limb ischemia in patients unsuitable for open surgery. Journal of Vascular Surgery. 2007. 17264008. Not stent
Therasse E, Cote G, Oliva VL, Cusson JR, Wi staff R, Nguyen PV, Bui BT, Perreault P, Lamarre L, Soulez G. Infrarenal aortic stenosis: value of stent placement after percutaneous transluminal angioplasty failure. Radiology. 2001. 11376250. Graft lesion
Treiman GS, Schneider PA, Lawrence PF, Pevec WC, Bush RL, Ichikawa L. Does stent placement improve the results of ineffective or complicated iliac artery angioplasty?. Journal of Vascular Surgery. 1998. 9685136. Not stent vs other
van de Ven, Kaatee R, Beutler JJ, Beek FJ, Woittiez AJ, Buskens E, Koomans HA, Mali WP. Arterial stenting and balloon angioplasty in ostial atherosclerotic renovascular disease: a randomised trial. Lancet. 1999. 9929021. Not PAD
Vogt KJ, Rasmussen JG, Just S, Schroeder TV. Effect and outcome of balloon angioplasty and stenting of the iliac arteries evaluated by intravascular ultrasound. European Journal of Vascular & Endovascular Surgery. 1999. 10071617. No clinical outcomes (st v other)
Whatling PJ, Gibson M, Torrie EP, Magee TR, Galland RB. Iliac occlusions: stenting or crossover grafting? An examination of patency and cost. European Journal of Vascular & Endovascular Surgery. 2000. 10906295. No clinical outcomes (st v other)
Wolfram RM, Budinsky AC, Pokrajac B, Potter R, Minar E. Endovascular brachytherapy for prophylaxis of restenosis after fernoropopliteal angioplasty: five-year follow-up--prospective randomized study. Radiology. 2006. 16926331. Not stent vs other
Zabakis P, Kardamakis DM, Siablis D, Kalogeropoulou C, Karnabatidis D, Malatara G, Dimopoulos IA. External beam radiation therapy reduces the rate of re-stenosis in patients treated with femoral stenting: results of a randomised study. Radiotherapy & Oncology. 2005. 15683662. Not stent vs other