# Search Strategy

Databases:

Ovid MEDLINE(R) (mesz), Ovid MEDLINE(R) Daily Update (mesx), Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations (prem), CCTR

# | Search History | Results
1 | Exp Stents/ or exp Vascular Surgical Procedures/ or exp Angioplasty, Balloon/ | 100,204
2 | Exp Atherectomy/ | 1,690
3 | Exp Limb Salvage/ | 634
4 | Exp Brachytherapy/ | 11,438
5 | embolectomy/ or endarterectomy/ or thrombectomy/ or saphenous vein/ or blood vessel prosthesis implantation/ | 26,032
6 | or/1–5 | 119,355
7 | Exp Intermittent Claudication/ or exp Peripheral Vascular Diseases/ or peripheral artery disease.mp. | 13,868
8 | Arterial occlusive diseases/ or arteriosclerosis/ | 74,855
9 | Arteriosclerosis Obliterans/ | 3,571
10 | Critical limb ischemia.mp. | 527
11 | or/7–10 | 88,845
12 | Exp graft occlusion, vascular/ | 6,711
13 | *femoral artery/ or *iliac artery/ or *popliteal artery/ or *tibial arteries/ | 16,553
14 | 12 or 13 | 22,595
15 | 6 and 11 | 10,758
16 | 6 and 14 | 8,553
17 | 15 or 16 | 16,270
18 | Limit 17 to humans [Limit not valid in: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations, CCTR; records were retained] | 14,815