# SimCare: A Model for Studying Physician Decisionmaking Activity

## Abstract

A major factor that contributes to the high rates of medical error in the treatment of patients with diabetes and other chronic diseases is the complexity of the tasks that physicians must complete. SimCare is a model of the clinical care setting for patients with type 2 diabetes. The model was designed to support investigation of physician cognition and decisionmaking activity. SimCare is dynamic and interactive and simulates diabetes management in the office-practice setting. SimCare presents a series of cases based on clinical situations representing task features that are thought to be the source of both realistic care decisions and medical errors. Once a simulated clinical case is initiated, physicians select treatment options (termed “moves”) from an unguided set of choices similar to those available in routine office practice. The cumulative record of the chosen treatment moves is available for analysis and comparison with an expert's sequence of moves for each simulated patient. SimCare is potentially both an assessment and a teaching tool that enables the observation and analysis of decisionmaking in the simulated practice setting. This paper discusses the use of this tool to identify potential sources of medical errors and guide customized learning interventions designed to reduce them.

## Clinical decisions in diabetes care

The clinical course of chronic illnesses such as diabetes mellitus type 2 is generally characterized by slowly changing states of health, with inherent variability in the rate of disease progression across patients. The detection of significant change in health status of individual patients may be masked by the subtle progression of the disease and its complications, and of common comorbid conditions. Physicians often fail to prescribe appropriate evidence-based treatment in patients who have not achieved recommended clinical goals for a variety of reasons. ^1^ There are several confounding variables that affect patients' response to treatment. For example, changes in socioeconomic status or health insurance coverage may alter patterns of care or medication adherence.

The cognitive challenges to physicians caring for those with a complex chronic disease such as diabetes are many. Some of the major cognitive tasks include—

- Selecting appropriate evidence-based clinical goals across multiple clinical domains (for example, glucose, blood pressure, cholesterol).
- Initiating appropriate therapy.
- Titrating therapy to achieve and maintain desired evidence-based goals.
- Detecting and effectively managing comorbid conditions, such as depression, that may interfere with diabetes treatment.

Computer-based models and simulation methods have been used to better understand and improve diabetes care. Diabetes Physiolab™ is a proprietary system that models disease at the level of enzymatic activity. ^2^ Other efforts have modeled general diabetes physiology (Sarimner), ^3^ pharmacokinetics, ^4^ specific glucose-insulin interactions as educational simulators (AIDA, DIABLOG), ^5,^ ^6^ as well as diabetes decision-support systems (DIAS-NIDDM). ^7^ The Global Diabetes Model, ^8^ a stochastic model of type 2 diabetes, has been developed to predict trends for diabetic individuals or populations. A recent model—Archimedes ^9^ —has simulated a continuous disease process at the individual patient level.

SimCare adds to these efforts in a number of respects. First, SimCare was designed to explore variability in physician decisionmaking and to map patterns of chronic disease care. Second, primary care physician involvement in its development assures that SimCare reflects the clinical terrain and cognitive challenges associated with primary care practice. Third, SimCare focuses on the outpatient clinical encounter as the primary level of description and interaction. SimCare has a broad therapeutic scope that includes the effect of oral diabetes medications, effects from referrals and advice to patient, in addition to the effect of prescribed insulin.

## The SimCare simulation

SimCare provides a dynamic and interactive simulation environment for the treatment of patients with type 2 diabetes. A set of outpatient cases is presented in sequence. Each case is managed through a series of virtual patient-physician encounters in a primary care clinic setting. The physician is able to perform the traditional subjective-objective-assessment plan (SOAP) approach to patient care. This format helps establish clinical plausibility and provides a framework for presenting data and accepting treatment moves. (Each treatment action made by the subject physician through the interface is a “move.”)

The simulation is an abstraction of the type 2 diabetes clinical setting, created for purposes of capturing physician treatment decisions. The goal of the simulation is to engage physician decisionmaking and solicit representative treatment moves. Given this focus on the clinical encounter, the simulation does not incorporate a complete model of diabetic pathophysiology.

The simulation begins with the selection of a patient case from a library of cases. Each case is presented in the form of a patient case history, with initial encounter data. The case data is composed of a set of attributes (variables) that change as a function of physician moves. In each encounter, the simulation moves through a cycle composed of presentation of patient data, collection of treatment moves, and generation of new patient data in response to moves. At the conclusion of each encounter, the physician schedules a subsequent visit. The simulation responds by presenting a new encounter with updated patient information. The update of the patient information is based on both the physician moves and on the amount of elapsed time. A unique disease trajectory, which depends on the specific series of moves made by the physician, unfolds for each simulated patient.

## SimCare components

The SimCare simulation has two parts: (1) a user interface (UI) that presents the patient state information and accepts physician moves, and (2) a patient model (PM) that updates the patient state in response to the treatment moves and the passage of time (Figure 1). The UI provides the environment of a clinical encounter. The PM generates information needed by the physician to make decisions with respect to treatment moves.

Figure 1 Physician interaction with SimCare

### The user interface (UI)

The SimCare UI presents patient data to the physician, transmits physician moves to the patient model, and preserves the clinical environment of continuous care over the encounters during which the patient is treated. There are two requirements of the UI: (1) the presented patient data must be organized and displayed in formats familiar to physicians, and (2) the physician should be able to make treatment moves in a familiar and acceptable manner.

The UI allows the physician to view patient information, including the physical exam report, recent lab results, current prescriptions, and a patient self-report. Explicit physiological data (such as blood pressure, glycated hemoglobin [HgbA1c], or a lipid panel) is provided in the physical exam report and laboratory results. Implicit behavioral (diet, exercise) and psychosocial information (adherence, depression) is provided through a patient self-report. The physician may change medications, give advice to the patient, order laboratory tests, and make referrals to specialists. At the conclusion of each encounter, the physician can schedule a subsequent visit.

A medication order form consists of a formulary and an insulin order matrix that allows the physician to prescribe different types of insulin at specific times of the day. A referral order form and laboratory test order form are modeled on those used in a large medical group practice. The physician is able to give advice to the patient on diet and exercise.

Treatment moves made by the physician are collected by the UI and sent to the patient model, which responds with an updated patient state. The new patient state information is sent to the UI and presented to the physician in the next encounter in the form of reports comprised of (1) a subjective patient self-report, (2) an objective physical exam report, (3) a self-monitored blood glucose (SMBG) log, (4) laboratory test results, and (5) referral response (if appropriate).

### The patient model (PM)

The PM is comprised of patient state attributes and a set of functions that update values of these attributes in response to physician moves. The PM takes into account the passage of time, i.e., the patient state update is contingent upon the time elapsed between encounters, in addition to the physician moves. Patient state attributes are grouped into physiological, psychosocial, and behavioral categories. The physiological attributes specify the physiological condition of the patient, while the behavioral attributes specify the current patient self-care behaviors. The psychosocial attributes affect patient compliance with prescriptions and physician recommendations.

### The patient state

The set of physiological, behavioral, and psychosocial attributes that comprise the patient state in the SimCare PM are shown in Figure 2. The physiological attributes change with respect to time and in response to physician moves. The selection of attributes is based on clinical treatment logic, as reflected in recent clinical guidelines and clinical literature regarding type 2 diabetes mellitus. ^10,^ ^11^ These attributes are key features in primary care management of patients with diabetes and collectively address common sources for physician errors: ^12^

- Insufficient awareness and treatment of cardiovascular risk factors.
- Confounding effects of depression on adherence to treatment regimen. ^13^
- Complications from drug therapies. ^10^

Figure 2 Physiological, psychosocial, and behavioral attributes of the patient model

The adherence attribute, which determines the extent to which the patient takes prescribed medications and follows physician recommendations for self-care, reproduces the effect of variation in patient compliance on patient behavior. The effect of the adherence attribute is modeled by giving the simulated patient a proportion (a value between 0 and 1) of a given prescription, as specified by the adherence value. For example, a patient prescribed Glipizide (20 mg q.d.) who has an adherence of 0.5 will only take 20*0.5 = 10 mg q.d. The patient follows the recommended diet and exercise to the extent dictated by the value of adherence. The effect of adherence as a moderator on all inputs to the functions in the PM is shown in Figure 3. Depression, common among patients with diabetes, ^13^ is one of the factors that adversely affect patient adherence to medication and self-care behavior regimens. ^14^ A patient self-report provides a narrative in each encounter that describes self-care behaviors and depression symptoms, if any. Patient adherence and depression are inferred from the narrative.

Figure 3 Functions in the patient model

### Physiological functions

Every physiological attribute has an associated physiological function that updates its value. The inputs to a function consist of factors that affect the value of the attribute, and the output is the new attribute value. For example, the inputs to the HgbA1c function are current values of diet, exercise, and doses of sulfonylureas, Metformin, thiazolidionediones (TZD), and insulin:

New HgbA1c = f (HgbA1c, diet, exercise, sulfonylureas, Metformin, TZDs, insulin)

As shown in Figure 3, each function sums the contribution of multiple physician moves, and time, to compute the new value of the attribute. The magnitude of the contribution of each move is specified by the magnitude of the move (e.g., drug dose), and its timing (when it is given). The former is computed using a dose-response table (specifying the magnitude of the effect), while the latter is computed using a dose-response schedule (specifying the attenuation of the medication effect over time).

Dose-response table. The dose-response table computes the maximum expected benefit of a given move, as well as the incremental benefits of titrating (adjusting) the move. In the case of medications, a dose-response table specifies the expected impact on the attribute that the drug affects at different dosages. There is a dose-response table for each drug move and the attribute that it affects, which was adopted from the Staged Diabetes Management Handbook. ^1^ For instance, as diet influences weight, blood pressure, and blood glucose, the dose-response tables for diet are diet-weight, diet-blood pressure, and diet-blood glucose.

The dose-response table is implemented as a sum that computes the effect of a given move. The utility of the additive form is that it can be positive or negative, depending upon the direction of the dose change, and is able to represent the bidirectional effects of incremental dose changes at any dose level. The general form of the function representing a dose-response table is

where m_0_ = current drug dose, m_1_ = last drug dose, and

Sgn(x) = -1 if x is negative,

1 if x is positive,

0 if x = 0

Dose-response schedule. The effect of a move made by a physician on patient state changes over time. ^1^ From the time that a move is made, the effect of the move increases gradually until its time of peak effect, when the entire effect of the move is manifest on the target patient variable. The proportion of the move's effect commensurate with the amount of time elapsed is computed as the patient's response to the change in treatment. This is accomplished in the PM by using a time coefficient that specifies the proportion of the effect.

Each move available in the simulation has an associated dose-response schedule that specifies the proportion of the move's effect that depends on the time elapsed since the move was made. Some moves reach their peak effect in a few days; others can take several weeks before the entire effect is manifest. The general form of the function that approximates the proportion of the drug effect as a result of time attenuation is

where n is the number of days till peak effect, T is actual time elapsed, and α and β are coefficients that determine the desired shape of the curve. The following functions are used for drugs that reach peak effect in 14 days and 90 days, respectively:

The simulated patient is updated from one encounter to the next. The incremental difference is computed by subtracting the total effect of a move on the current encounter from the total effect until the last encounter. The dose-response function facilitates this computation with the functional form

where Today is the date of current encounter, LastVisitDate is the date of last encounter, and doseDate_i_ is the date of move for all moves i = 0..n

The incremental effect of a move at a given time is computed by multiplying the output of the dose-response table with the output of the dose-response schedule. The clinical impact of various drugs on HgbA1c, low-density lipoproteins (LDL), or blood pressure (BP) is modeled using published pharmacokinetic data. ^15,^ ^16^

### Psychosocial functions

The effect of adherence on physiological variables is modeled using psychosocial functions for adherence and depression. The inputs to the PM function that updates adherence are (1) current adherence, (2) depression, (3) nurse educator referral (if any), and (4) dietitian referral (if any). The inputs to the depression function are (1) current level of depression, (2) psychologist referral (if any), and (3) medications (i.e., Zoloft).

Psychosocial functions are modeled using fuzzy logic, which allows quantification of linguistic variables. Psychosocial attributes of stress and depression are described with verbal modifiers: “low,” “medium,” and “high.” The relationships between the psychosocial attributes are described linguistically—e.g., “If stress is high, then blood pressure increases” and “If depression is high, then adherence is low.” The four-step method described by Kosko in 1993 was used for computing adherence from depression and stress: ^17^

1 Fuzzification. Develop a membership function to map the verbal description of variable (low, medium, high) to a numeric scale.
2 Rule base. Express each relationship between an independent psychosocial variable, such as depression, and a dependent variable, such as adherence, in a fuzzy rule. For example, “IF High Depression THEN Low Adherence.”
3 Inferencing. Compute the fuzzy value (set membership) of the dependent variable by using the value of the independent variable and the fuzzy rules.
4 Defuzzification. Convert the fuzzy value of the dependent variable to a specific numeric value. We use the “centroid” method of defuzzification in which the center of mass provides the crisp value. The center of mass is calculated by first treating each output set as a point mass, and then calculating the center of gravity for those point masses distributed along the “x” axis. We then find the center of gravity of the output point masses using the formula

sum of the moments ÷ sum of the masses.

This method favors the rule with the greatest area as contrasted with the alternative “height” method, which takes the value of the biggest contributor.

Adherence changes nonlinearly in response to the combined effects of stress and depression. In one case, a cycle in the psychosocial functions causes reinforcing effects of changes between depression and adherence (Figure 3)—creating a “virtuous circle.” When depression is treated with medication, it improves adherence, which in turn increases the amount of depression medication that is taken, improving depression further. In another case, the patient adherence could drop after depression symptoms have been resolved. The self-report patient narrative is generated in the UI by a look-up table that contains statement modifiers for low, medium, or high levels of adherence and depression.

## SimCare implementation

The simulation is implemented through (1) a UI programmed in Visual Basic™, (2) an Access™ relational database (DB), and (3) a rule-based engine that embodies the PM. The DB stores the patient case library, historical and current patient state information, and a record of physician moves. The simulation begins with loading a patient case from the case library into the UI. At this start point, the DB consists of only the initial encounter information for each patient in the case library. The DB is updated with subsequent encounters as the simulation progresses. The UI and rule-based engine were developed using Visual Basic to allow rapid initial prototyping through an object-oriented interface, and ease of interfacing with the Access database application.

## Validation and verification

Validation has been defined by Law as “the process of determining whether a simulation model is an accurate representation of the system, for the particular objectives of the study.” ^18^ SimCare's primary objective was to represent a virtual clinical encounter for patients with type 2 diabetes and to achieve sufficient clinical plausibility that representative patient management actions would be elicited.

In the SimCare project, Sargent's definition of model verification is used: “ensuring that the computer program of the computerized model and its implementation are correct.” ^19^ Software constructs such as object-oriented programming and program modularity were used to reduce implementation error. Both static “structured walk-throughs” ^18^ and dynamic testing were performed as a part of the model verification process. Structured walk-throughs were performed with an expert physician panel at two levels—with the conceptual model to validate the simulation's representation (described below), and with the programmed simulation to verify the computer model implementation.

## Conceptual, operational, and face validity

Conceptual validity addresses the question of how well the components of the model and their interactions represent the phenomenon under investigation—in this case, the clinical encounter. The conceptual model of the clinical encounter and the key patient variables in the treatment of type 2 diabetes, in the SimCare model, are based on clinical treatment guidelines (Institute for Clinical Systems Integration [ICSI]), the Staged Diabetes Management, and the American Diabetes Association (ADA). ^1,^ ^10,^ ^11^ The physiological responses in the PM are based on clinical literature ^15^ and the documented effect of psychosocial factors and their impact on treatment. ^20,^ ^21^ A panel of expert physicians stepped through the process of managing an encounter in the conceptual model description to determine if the representation of the clinical encounter was appropriate for SimCare's purpose. The SimCare UI design was based on common formats of receiving information and taking action familiar to the physicians (medication order form, laboratory test order form, referral order form, physical exam report, etc.).

Operational validity determines if the model's output “has the accuracy required for the model's intended purpose over the domain of its intended applicability.” ^19^ Model responses were studied to determine if they were

- Within valid clinical bounds.
- Robust to extreme or multiple inputs.
- Sensitive to small changes in the input.

These questions were addressed using “extreme condition tests,” in which the model output was examined for extreme and unlikely combinations of values. In addition, “degenerate tests,” which involve the degeneracy of the model's behavior, were performed. The tests conducted on SimCare that involved changing the values of the model inputs in small and large increments to determine the effect on outputs are referred to as “parameter variability-sensitivity analysis.” The PM response to these series of experiments were graphed and reviewed by the panel of consulting physicians.

Face validity, defined by Sargent as “asking people knowledgeable about the system whether the model and/or its behavior are reasonable,” ^19^ was deemed sufficient for the purpose of generating plausible patient responses.

## SimCare experimental data

SimCare was required to fulfill the primary criterion: “Can it be used by physicians to make decisions on patients who are portrayed in clinical contexts?” The patient response had to be plausible not just for a particular physician move, but for a series of moves. Table 1 shows a summary of experimental data for one subject, and Figure 4 is a graph of the subject's moves that is available as a followup to the experiment. Table 1 has three sections: (1) lab test orders and referrals, (2) medication moves, and (3) the patient's state. Each column shows a physician-patient encounter. The table entries show the time stamp in parentheses for when a move was made. For example, “*(327)” in the first encounter (Lab Orders section/TSH_Order row) indicates that a measurement of thyroid stimulating hormone was made 327 seconds into the case. The physician subject is able to view only those patient state variables for which a test was ordered. Depression and adherence are conveyed through the patient response and self-report narrative.

Figure 4 Experimental data: HgbA1c trace

Table 1 Experimental data: decision graph of a physician's treatment of a case

Decision Graph for Physician 5X
PtntId | 16
Visit Number | 0 (Initial data) | 1 | 2 | 3 | 4
Encounter Date | | 01/01/2001 | 01/15/2001 | 02/12/2001 | 03/12/2001
Visit Type | | Visit | Visit | Visit | Phone
Lab Orders
HgbA1c | | v(94) | v(735) | v(885)
SMBG | | v(481)*(529) | v(600) | v(1000) | v(1079)
Creatinine | | v(98)*(311) | v(740) | v(891)
Lipids | | v(95) | v(737)
ALT | | *(309)
TSH_Order | | *(327)
UMACR | | *(332)
CPK | | *(314)
GL | | *(337)
Referrals | | Psych,DE, Opth,Diet | Endo
Meds
Aspirin | | 325q.d.(228) | 325q.d. | 325q.d.
Atorvastatin | 20q.d. | 40q.d.(217) | 40q.d. | 40q.d.(980)
Hydrochlor | 25q.d. | 0q.d.(291)
Lisinopril | | 10q.d.(299) | 10q.d. | 10q.d.
Metformin | 500b.i.d. | 500b.i.d. | 0b.i.d.(771)
Rosiglitazone | | | | 4q.d.(956)
Zoloft | | | 50q.d. | 50q.d.
Insulin | 75R 60N | 75R 65N(485) | 81R 75N(681) | 81R 75N(1015) | 81R 75N(1090)
Patient State
A1c | 10.5 | 10.5 | 9.9 | 8.3 | 7.4
Avg. SMBG | 267 | 261 | 229 | 165 | 146
Adherence | .5 | .5 | 1.0 | 1.0 | 1.0
LDL | 157 | 157 | 139 | 120 | 117
HDL | 28 | 27 | 30 | 32 | 33
Triglycerides | 380 | 380 | 332 | 263 | 252
Systolic | 150 | 153 | 138 | 131 | 131
Creatinine | 1.5 | 1.5 | 1.8 | 1.9 | 1.9
Depression | 60 | 60 | 30 | 0 | 0

[underlined: Legend]: * = Lab Order, v = View Lab Values, DE = Diabetes Educator, Diet = Dietician, Opth = Ophthalmologist, Pod = Podiatrist, Psych = Psychiatrist. The number in parenthesis indicates the time stamp of the move.

(All dosages are qd unless otherwise noted.)

Figure 4 shows a graph of the patient HgbA1c response to physician moves. Similar graphs are available for lipids and blood pressure. In the project for which the simulation was developed, 40 physicians treated a set of simulated patients using the SimCare model.

## Summary and conclusion

SimCare has several limitations. First, the SimCare UI departs from the actual encounter environment, as it removes some of the barriers faced in actual encounters and provides an ease of performing moves that is not found in actual care. Second, a computer simulation is unable to replicate the wealth of information that the physician gathers from a conversation and face-to-face meetings with a patient. In the SimCare simulation, the physician is limited to behavioral recommendations to the patient and a patient self-report. Third, SimCare's abstracted encounter minimizes the reality of potential psychosocial and economic barriers to care that patients face in reality.

Despite these limitations, the SimCare simulation has a variety of potential applications. First, the information obtained can be a powerful tool in the effort to identify appropriate moves, as well as errors, in the care of adults with diabetes. It is possible to map a given physician's decision processes with respect to diabetes care, and identify both specific strengths and opportunities for improvement in the core cognitive tasks that underlie decisions regarding chronic disease care.

Examples of problems uncovered by analysis of the SimCare case management data include failure to recognize comorbid depression (as indicated by lack of treating depression in instances where the patient is not responsive to treatment and self-reports depressive symptoms); inability to initiate insulin when necessary; failure to titrate insulin as appropriate; failure to recognize evidence-based goals for HgbA1c, BP, or lipid control; and lack of familiarity with common contraindications to the use of medications (such as Metformin).

Physician performance on the SimCare cases can also be used to guide learning interventions tailored to a given physician's patterns of care. Thus, if one physician demonstrates underuse of therapy such as insulin, teaching cases that emphasize key aspects of insulin treatment may be provided as a learning intervention for that physician. Likewise, physicians who habitually miss the diagnosis of comorbid depression can receive learning interventions that help develop that skill.

With additional development, SimCare cases could be used proactively with physicians early in their professional careers, to guide the development of core competencies in chronic disease care. The cases were given, as a pilot study, to a series of family practice residents and faculty who were able to recognize the value of the simulated case management as a powerful clinical teaching tool. The relevance and potential application of such learning tools may increase due to statutory limits imposed on residency training hours and the need to supplement “real” patient care experiences with high-volume, “simulated” cases with embedded teaching points.

Finally, the model now includes measures of resource use linked to visits, prescriptions, tests, and referrals. These measures enable physicians to receive feedback on the ratio of clinical benefit to resource use engendered for specific patterns of diabetes care. This may lead to recognition by individual physicians of inefficient patterns of resource use in diabetes care. A further extension would be to use the model to simulate the costs of various diabetes care protocols across populations of diabetes patients.

## Acknowledgments

This work was supported by grant #R01 HS10639-01A1 from the Agency for Healthcare Research and Quality (AHRQ).

## References

1 Mazze R, Strock E, Simonson G, et al., Staged diabetes management: detection and treatment. Minneapolis, MN: International Diabetes Center; 2001.
2 Entelos diabetes physiolab. Foster City, CA: Entelos, Inc.; 2003.
3 Hedbrant J, Ludvigsson J, Nordenskjold K. Sarimner: a computer model of diabetes physiology for the education of physicians and patients. Diabetes Res Clin Pract. 1991;14(2):113-22. [pmid: 1756682].
4 Wada DR, Stanski DR, Ebing WF. A PC-based graphical simulator for physiological pharmacokinetic models. Comput Methods Programs Biomed. 1995;46:245-55. [pmid: 7656558].
5 Lehmann ED, Deutsch T. A physiological model of glucose-insulin interaction. Proc Ann Conf Engin Med Biol. 1991;13(5):2274-5.
6 Biermann E, Mehnert H. DIABLOG: a simulation program of insulin-glucose dynamics for education of diabetes. Comput Methods Programs Biomed. 1990;32(34):311-8. [pmid: 2249430].
7 Romulus T, Hovorka R, Cavan D, et al. DIAS-NIDDM: a model-based decision support system for insulin dose adjustment in insulin-treated subjects with NIDDM. Comput Methods Programs Biomed. 1998;56:175-92. [pmid: 9700432].
8 Brown JB, Russell A, Chan W, et al. The global diabetes model: user-friendly version 3.0. Diabetes Res Clin Pract. 2000;50(Suppl. 3):S15-S46. [pmid: 11080561].
9 Eddy DM, Schlessinger L. Archimedes: a trial-validated model of diabetes. Diabetes Care 2003;26(11):3093 (9).
10 Institute for Clinical Systems Integration. Health care guideline: management of type 2 diabetes mellitus. Bloomington MN: Institute for Clinical Systems Integration; 2003.
11 American Diabetes Association Professional Practice Committee. 2003 clinical practice guidelines. Diabetes Care. 2003;26(Suppl 1):1-116. [pmid: 12502651].
12 O'Connor P, Sperl-Hillen JM, Johnson PE, et al. Identification, classification, and frequency of medical errors in outpatient diabetes care. In: Henriksen K, Battles JB, Marks ES, Lewin DI, editors. Advances in patient safety: from research to implementation. Vol. 1, Research findings. AHRQ Publication No. 05-0021-1. Rockville, MD: Agency for Healthcare Research and Quality; 2005.
13 Ciechanowski PS, Katon WJ, Russo JE. Depression and diabetes: impact of depressive symptoms on adherence, function, and costs. Arch Intern Med. 2000;160(21):3278-85. [pmid: 11088090].
14 Lustman PJ, Anderson RJ, Freedland KE, et al. Depression and poor glycemic control: a meta-analytic review of the literature. Diabetes Care. 2000;23(7):934-42. [pmid: 10895843].
15 Defronzo R. Pharmacologic therapy for type 2 diabetes mellitus. Ann Intern Med. 1999;131(4):281-303. [pmid: 10454950].
16 Rickheim PL, Weaver TW, Flader JL, et al. Assessment of group versus individual diabetes education: a randomized study. Diabetes Care. 2002;25(2):269-74. [pmid: 11815494].
17 Kosko B. Fuzzy thinking—the new science of fuzzy logic. New York: Hyperion; 1993.
18 Law AM. Building valid models: how to build valid and credible simulation models. In: Peters BA, Smith JS, Medeiros DJ, et al., editors. Proc 33rd Conf Winter Simul; 2001; Washington, DC: IEEE Computer Society; 2001 pp. 22–9.
19 Sargent RG. Validation and verification of simulation models. In: Farrington PA, Nembhard HB, Sturrock DT, et al., editors. Proc 31st Conf Winter Simul: Simulation—a bridge to the future. Phoenix, AZ: ACM Press; 1999.
20 Gavard JA, Lustman PJ, Clouse RE. Prevalence of depression in adults with diabetes. An epidemiological evaluation. Diabetes Care. 1993;16(8):1167-78. [pmid: 8375247].
21 Lustman PJ, Griffith LS, Clouse RE. Depression in adults with diabetes. Semin Clin Neuropsychiatry. 1997;2(1):15-23. [pmid: 10320439].