# Peer Reviewers—Volume 4

The editors wish to thank the following individuals for acting as peer reviewers for manuscripts submitted for publication in Volume 4 of Advances in Patient Safety: From Research to Implementation:

James Battles

Richard Cook

Christine Crofton

Katherine Crosson

Charles Darby

Bradley Evanoff

Mike FitzMaurice

Steve Grimes

Louis Halamek

Kerm Henriksen

Madeleine Hess

John Hickner

Heidi King

Eric Marks

Pamela Mitchell

Bob Murphy

Veronica Nieva

Patrick O'Connor

Mary Pittman

Geoffrey Rake

Paul Schyve

Stephen Small

Leif Solberg

Joann Sorra

Howard Steed

David Stevens

Bruce Thomadsen

Eric Thomas

Joyce Verran

Nicholas Warren

Matthew Weinger