# Surveys

Online Patient Safety Climate Survey: Tool Development and Lessons Learned

Safety Climate on Hospital Units: A New Measure

Outpatient Surgery and Patient Safety— The Patient's Voice

An Employee Questionnaire for Assessing Patient Safety in Outpatient Surgery

Development and Validation of the Medication Administration Error Reporting Survey