# Surveillance Tools

Serious Reportable Adverse Events in Health Care

Physician Event Reporting: Training the Next Generation of Physicians

Standardizing Medication Error Event Reporting in the U.S. Department of Defense

Quality Indicators Sensitive to Nurse Staffing in Acute Care Settings

The Incident Decision Tree: Guidelines for Action Following Patient Safety Incidents

Technology for Improving Medication Monitoring in Nursing Homes