# Education and Training

AHRQ WebM&M—Online Medical Error Reporting and Analysis

Patient Safety Executive Walkarounds

Combining Performance Feedback and Evidence-based Educational Resources

Medical Team Training Programs in Health Care

The University of Wisconsin-Madison Multidisciplinary Graduate Certificate in Patient Safety

Expediting Clinician Adoption of Safety Practices: The UCSF Venous Access Patient Safety Interdisciplinary Education Project

Creating a Curriculum for Training Health Profession Faculty Leaders

An Ambulatory Care Curriculum for Advancing Patient Safety

Developing a Taxonomy of Anesthetists' Nontechnical Skills (ANTS)