# Simulation

The Use of Surgical Simulators to Reduce Errors

SimCare: A Model for Studying Physician Decisionmaking Activity

Standardized Simulated Events for Provocative Testing of Medical Care System Rescue Capabilities