# Tools and Procedures

Development of a Planning Tool to Guide Research Dissemination

Dissemination Planning Tool: Exhibit A

Physician Use of Hand-held Computers for Drug Information and Prescribing

A Process-centered Tool for Evaluating Patient Safety Performance and Guiding Strategic Improvement

Development of a Screening Tool for Safe Wheelchair Seating

Speaking Plainly: Communicating the Patient's Role in Health Care Safety

Standardizing Ambulatory Care Procedures in a Public Hospital System to Improve Patient Safety