# Programs and Collaborations

A Strategic Approach for Funding Research: The Agency for Healthcare Research and Quality's Patient Safety Initiative 2000-2004

Safe Practices for Better Health Care

The San Diego Center for Patient Safety: Creating a Research, Education, and Community Consortium

Best Practices for Medical Technology Management: A U.S. Air Force-ECRI Collaboration

A Clinical Assessment Program to Evaluate the Safety of Patient Care

A Nonpunitive, Computerized System for Improved Reporting of Medical Occurrences