# Peer Reviewers—Volume 3

The editors wish to thank the following individuals for acting as peer reviewers for manuscripts submitted for publication in Volume 3 of Advances in Patient Safety: From Research to Implementation:

Carmen Birk

C. Andrew Brown

Mark Bruley

John Combes

Ann Cook

Denise Dougherty

Timothy Dresselhaus

Stanley Edinger

Victoria Fraser

Marvin Fried

Caren Ginsberg

Paul Gorman

Kerm Henriksen

Edmund Howe

Elizabeth Hoy

Kevin Johnson

Robert Kane

Harold Kaplan

Mark Keroack

David Lewin

Mark Linzer

Colin Mackenzie

Glenn Merchant

Veronica Nieva

Bridget Olson

Victoria Parker

Ginette Pepper

Peter Pronovost

Kimberly Rask

Nancy Ridley

Gordon Schiff

Paul Schyve

Jill Scott-Cawiezell

Joann Sorra

Sarah Tackett

Eric Thomas

Alan White

Jay Wolfson