# Safety Improvement Initiatives

Behind the Scenes: Patient Safety in the Operating Room and Central Materiel Service During Deployments

Surgical Safety: Addressing the JCAHO Goals for Reducing Wrong-site, Wrong-patient, Wrong-procedure Events

Voluntary Hospital Coalitions to Promote Patient Safety

Suicide Risk Response: Enhancing Patient Safety Through Development of Effective Institutional Policies

A New Model of Tracheostomy Care: Closing the Research–Practice Gap