# Challenges and Lessons Learned

Patient Safety Data Sharing and Protection from Legal Discovery

Does Medical Error Disclosure Violate the Medical Malpractice Insurance Cooperation Clause?

Beyond the Dusty Shelf: Shifting Paradigms and Effecting Change

From Insight to Implementation: Lessons from a Multi-site Trial of a PDA-based Warfarin Dose Calculator

Lessons in Safety Climate and Safety Practices from a California Hospital Consortium

Systemwide Deployment of Medical Team Training: Lessons Learned in the Department of Defense

Barcode Medication Administration: Lessons Learned from an Intensive Care Unit Implementation

Institutional Review Board Approval of Practice-based Research Network Patient Safety Studies