# Interventions

The Impact of Personal Digital Assistant Devices on Medication Safety in Primary Care

Implementation of an Evidence-based Protocol for Surgical Infection Prophylaxis

Reducing the Use of Short-acting Nifedipine by Hypertensives Using a Pharmaceutical Database

Can an Academic Health Care System Overcome Barriers to Clinical Guideline Implementation?

Implementing a Systems Engineering Intervention for Improving Safety in Outpatient Surgeries

Improving the Safety of Heparin Administration by Implementing a Human Factors Process Analysis

Establishing a Culture of Patient Safety Through a Low-tech Approach to Reducing Medication Errors

Cost Effectiveness of a Multifaceted Program for Safe Patient Handling