# Surveillance

Using Reported Primary Care Errors to Develop and Implement Patient Safety Interventions: A Report from the ASIPS Collaborative

The AAFP Patient Safety Reporting System: Development and Legal Issues Pertinent to Medical Error Tracking and Analysis

Lessons Learned from the Evolution of Mandatory Adverse Event Reporting Systems

Shared Learning and the Drive to Improve Patient Safety: Lessons Learned from the Pittsburgh Regional Healthcare Initiative

Identifying Barriers to the Success of a Reporting System

“Near-miss” Reporting System Development and Implications for Human Subjects Protection

The Impact of a Web-based Reporting System on the Collection of Medication Error Occurrence Data

Ten Considerations for Easing the Transition to a Web-based Patient Safety Reporting System

Identifying, Understanding, and Communicating Medical Device Use Errors: Observations from an FDA Pilot Program

Implementation of a Data-based Medical Event Reporting System in the U.S. Department of Defense